# Prioritized Research Questions Within Scope of Original CER

Priority level | Research question | Total number of stars
High | Among individuals who are not responding to usual asthma care, what is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma? | 8
High | What is the effectiveness or comparative effectiveness of breathing techniques among individuals with anxiety and/or panic disorders (with and without asthma)? | 8
High | What is the effectiveness of multicomponent asthma interventions (i.e., incorporating breathing techniques, relaxation techniques, and other lifestyle modifications) on asthma outcomes? | 8
High | What is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma among children and adolescents, and specifically adolescent females? | 7
High | What is the effectiveness or comparative effectiveness of breathing techniques among individuals with varying levels of asthma severity and which individuals (i.e., those with mild, moderate, or severe asthma) benefit the most from using breathing techniques to help manage their asthma? | 6
Medium | What is the effectiveness or comparative effectiveness of breathing techniques among individuals with sleep apnea (with and without asthma)? | 5
Medium | What are the characteristics of individuals with asthma who benefit the most from breathing technique interventions? | 5
Medium | What is the effectiveness or comparative effectiveness of the standard Buteyko breathing intervention (as set forth by the Buteyko Breathing Educators Association) on asthma outcomes compared with usual asthma care or other breathing techniques? | 5
Low | Among individuals who are not adherent to usual care, what is the effectiveness or comparative effectiveness of breathing techniques in the treatment of asthma? | 3
Low | What is the optimal intensity and duration of breathing techniques interventions? | 3
Low | What is the effectiveness or comparative effectiveness of breathing techniques among individuals who experience high levels of stress (with and without asthma)? | 2
Low | What is the effectiveness or comparative effectiveness of breathing techniques among individuals with vocal cord dysfunction (with and without asthma)? | 2
Low | What is the comparative effectiveness of breathing techniques plus dietary modifications versus dietary modifications alone in the treatment of asthma? | 2
Low | What is the effectiveness of specific breathing techniques on end-tidal carbon dioxide? | 1
Low | What is the effectiveness or comparative effectiveness of the POWERbreathe® inspiratory muscle trainer on asthma outcomes? | 0
Low | What is the independent effect of the specific breathing techniques used in school-based asthma education programs (e.g., Open Airways, Power Breathing) on children/adolescent asthma outcomes? | 0