# Literature Search Strategies

Database: AltHealthWatch
S16 S1 and S15
S15 S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14
S14 TI biofeedback or AB biofeedback
S13 TI diaphragmatic breath* or AB diaphragmatic breath*
S12 AB ( diaphragm* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S11 AB ( breath* or respirat* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S10 TI ( breath* or respirat* ) and TI ( exercise* or training or retraining or pattern* or technique* )
S9 TI ( breath* or respirat* ) and TI ( paced or pursed )
S8 AB ( breath* or respirat* ) and AB ( paced or pursed )
S7 AB ( breath* or respirat* ) and AB ( physiotherap* or physical therap* )
S6 TI ( breath* or respirat* ) and TI ( physiotherap* or physical therap* )
S5 TI Pranayama or AB Pranayama
S4 TI Buteyko or AB Buteyko
S3 TI yogic OR AB yogic
S2 TI yoga OR AB yoga
S1 TI asthma* or AB asthma*

Database: CINAHL
S27 S3 and S25 Limiters - Published Date from: 19900101-20120625
S26 S3 and S25
S25 S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24
S24 TI biofeedback or AB biofeedback
S23 (MH “Biofeedback”) OR (MH “Biofeedback (Iowa NIC)”)
S22 TI diaphragmatic breath* or AB diaphragmatic breath*
S21 TI diaphragm* and TI ( exercise* or training or retraining or pattern* or technique* )
S20 AB diaphragm* and AB ( exercise* or training or retraining or pattern* or technique* )
S19 AB ( breath* or respirat* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S18 TI ( breath* or respirat* ) and TI ( exercise* or training or retraining or pattern* or technique* )
S17 TI ( breath* or respirat* ) and TI ( paced or pursed )
S16 AB ( breath* or respirat* ) and AB ( paced or pursed )
S15 AB ( breath* or respirat* ) and AB ( physiotherap* or physical therap* )
S14 TI ( breath* or respirat* ) and TI ( physiotherap* or physical therap* )
S13 TI “expiratory muscle training” or AB “expiratory muscle training”
S12 TI “inspiratory muscle training” or AB “inspiratory muscle training”
S11 TI Papworth or AB Papworth
S10 TI Pranayama or AB Pranayama
S9 TI Buteyko or AB Buteyko
S8 TI yogic or AB yogic
S7 TI yoga or AB yoga
S6 (MH “Yoga”) OR (MH “Yoga Pose”)
S5 (MH “Breathing Exercises (Saba CCC)”)
S4 (MH “Breathing Exercises”) OR (MH “Buteyko Method”)
S3 s1 or s2
S2 TI asthma* or AB asthma*
S1 (MH “Asthma”) OR (MH “Asthma, Exercise-Induced”) OR (MH “Status Asthmaticus”)

Database: Cochrane Central Register of Controlled Trials
#1 asthma*:ti,ab,kw
#2 “breathing exercises”:ti,ab,kw
#3 yoga:ti,ab,kw
#4 yogic:ti,ab,kw
#5 Buteyko:ti,ab,kw
#6 Pranayama:ti,ab,kw
#7 Papworth:ti,ab,kw
#8 “inspiratory muscle training”:ti,ab,kw
#9 “expiratory muscle training”:ti,ab,kw
#10 breath*:ti or respirat*:ti
#11 physiotherap*:ti or physical therap*:ti
#12 (#10 AND #11)
#13 breath*:ab or respirat*:ab
#14 physiotherap*:ab or physical therap*:ab
#15 (#13 AND #14)
#16 paced:ti,ab or pursed:ti,ab
#17 (( #11 OR #14 ) AND #16)
#18 exercise*:ti or training:ti or retraining:ti or pattern*:ti or technique*:ti
#19 (#10 AND #18)
#20 exercise*:ab or training:ab or retraining:ab or pattern*:ab or technique*:ab
#21 (#13 AND #20)
#22 diaphragm*:ti,ab
#23 (#22 AND ( #18 OR #20 ))
#24 diaphragmatic next breath*
#25 biofeedback:ti,ab,kw
#26 (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #12 OR #15 OR #17 OR #19 OR #21 OR #23 OR #24 OR #25)
#27 (#1 AND #26), from 1990 to 2012

Database: CSA
- KW=asthma AND KW=(Buteyko OR Pranayama OR Papworth OR yoga OR yogic OR biofeedback OR “inspiratory muscle training” OR “expiratory muscle training” OR “breathing physical therapy” OR “breathing physiotherapy” OR paced OR pursed OR “breathing exercise*” OR “breathing training” OR “breathing retraining” OR “diaphragmatic breathing” OR “breathing technique*”)

Database: EMBASE <1988 to 2012 June 25>
1. asthma/ or allergic asthma/ or asthmatic state/ or exercise induced asthma/ or extrinsic asthma/ or intrinsic asthma/ or mild intermittent asthma/ or mild persistent asthma/ or moderate persistent asthma/ or nocturnal asthma/ or occupational asthma/ or severe persistent asthma/
2. asthma$.ti,ab.
3. 1 or 2
4. breathing exercise/
5. YOGA/
6. yoga.ti,ab.
7. yogic.ti,ab.
8. Buteyko.ti,ab.
9. Pranayama.ti,ab.
10. Papworth.ti,ab.
11. “inspiratory muscle training”.ti,ab.
12. “expiratory muscle training”.ti,ab.
13. ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
14. ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
15. ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16. (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
17. diaphragmatic breath$.ti,ab.
18. feedback system/
19. biofeedback.ti,ab.
20. or/4-19
21. 3 and 20
22. limit 21 to yr=“1990 -Current”
23. limit 22 to english language

Database: IndMED
- asthma
- AND
- buteyko OR
- yoga OR
- yogic OR
- papworth OR
- pranayama OR
- biofeedback OR
- expiratory muscle training OR
- inspiratory muscle training OR
- breathing physical therapy OR
- breathing physiotherapy OR
- paced OR
- pursed OR
- breathing exercise OR
- breathing exercises OR
- breathing training OR
- breathing retraining OR
- diaphragm breathing OR
- breathing technique OR
- breathing techniques OR
- breathing pattern OR
- breathing patterns

Database: Ovid MEDLINE(R)
1. asthma/ or asthma, exercise-induced/ or status asthmaticus/
2. asthma$.ti,ab.
3. 1 or 2
4. Breathing Exercises/
5. Yoga/
6. yoga.ti,ab.
7. yogic.ti,ab.
8. Buteyko.ti,ab.
9. Pranayama.ti,ab.
10. Papworth.ti,ab.
11. “inspiratory muscle training”.ti,ab.
12. “expiratory muscle training”.ti,ab.
13. ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
14. ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
15. ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16. (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
17. diaphragmatic breath$.ti,ab.
18. biofeedback, psychology/
19. biofeedback.ti,ab.
20. 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21. 3 and 20
22. limit 21 to yr=“1990 -Current”
23. remove duplicates from 22
24. limit 23 to english language

Database: PEDRO
- asthma
- AND
- buteyko OR
- yoga OR
- yogic OR
- papworth OR
- pranayama OR
- biofeedback OR
- expiratory muscle training OR
- inspiratory muscle training OR
- breathing physical therapy OR
- breathing physiotherapy OR
- paced OR
- pursed OR
- breathing exercise OR
- breathing training OR
- breathing retraining OR
- diaphragm breathing OR
- breathing technique OR
- breathing pattern

Database: PsychINFO
1. asthma/
2. asthma$.ti,ab.
3. 1 or 2
4. yoga/
5. yoga.ti,ab.
6. yogic.ti,ab.
7. Buteyko.ti,ab.
8. Pranayama.ti,ab.
9. Papworth.ti,ab.
10. “inspiratory muscle training”.ti,ab.
11. “expiratory muscle training”.ti,ab.
12. ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
13. ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
14. ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
15. (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16. diaphragmatic breath$.ti,ab.
17. biofeedback/ or biofeedback training/
18. biofeedback.ti,ab.
19. or/4-18
20. 3 and 19
21. limit 20 to yr=“1990 -Current”
22. limit 21 to english language

For all other databases (e.g., CSA Proceedings, etc.):

asthma AND (buteyko OR pranayama OR papworth OR yoga OR yogic OR biofeedback OR paced OR pursed OR “muscle training” OR “physical therapy” OR physiotherapy OR “breathing exercise” OR “breathing exercises” OR “breathing training” OR “breathing retraining” OR “diaphragmatic breathing” OR “breathing technique” OR “breathing techniques”)