# Online Prioritization Software

Appendix B are screenshots of the online prioritization software as developed for this FRN project. The list of questions can be found in Appendix D and E.