# Interview Script

Introduction
- Thank you for agreeing to help us with this project.
- The interview should take 30 to 45 minutes.
- Did you receive the list of evidence gaps that we e-mailed?
- Let me tell you a little bit about this project: Although we identified 22 studies to include in our review, we identified multiple areas where insufficient evidence existed to answer our Key Questions and general evidence gaps related to this topic. The list that we provided you summarizes the broad future research needs that were identified throughout the review process. However, we understand that this list might not be exhaustive and there may be other research needs in this area that are important to clinicians, other practitioners, researchers, and patients. The purpose of this project is to develop and prioritize a future research agenda to close evidence gaps identified from this systematic review.
- We are aiming to recruit another 10 individuals to help us with this project who represent clinicians and practitioners, federal agencies who fund such research, representatives from asthma patient advocacy groups, and asthma researchers.
- We know that there are a lot of research needs and questions related to asthma management in children and adults. However, for this project, we want to stay focused on the research agenda related to the use of breathing techniques and exercises and other complementary and alternative therapies in the management of asthma. If our conversation starts to drift into a broader discussion of asthma management, I might try to steer us back to this.
- Before we jump into specific research questions, can you tell me a little bit about yourself and any research you have been involved with on this topic or the level of familiarity you have with this topic.

Interview Questions
1. After looking at the full list we provided, do you feel that this list is comprehensive?
2. If not, what other research questions do you think are important to consider?
3. Are there better ways to express any of these research topics? What suggestions do you have to improve the clarity of the wording?
4. Are there specific questions or topics on this list that seem like they are out of place or do not belong on this list in terms of their importance to the field?
5. Thinking specifically about different populations, interventions, and outcomes…
  a. Are there particular populations where more research is required?
  b. What types of interventions do you believe are most important to study?
  c. What outcomes do you believe are most important to include?
6. Are there any emerging areas of research or practice in the area of complementary and alternative strategies for managing asthma that are not reflected in this list?
7. Specifically for patient advocates:
  a. Are there any other questions that you have heard expressed by patients or other people in this field that might be good candidates for research in this area?
8. Specifically for trialists:
  a. If you were given funding to conduct a large research study in this area, what would that study look like? (We do not need to get into specific study methods or design issues, but rather what populations, intervention, and outcomes you would be interested in.)

Conclusions and wrap-up
- Before we wrap things up and talk about next steps, are there any last comments you have regarding this area of research?
- As I mentioned earlier, we are planning to speak with up to 10 individuals conducting research or practicing in this area. Once this list is finalized, we will send you an e-mail with a link to an online questionnaire in which we will ask to you rank the research questions according to the level of priority you believe they each have. Our goal in the end is to have a list of important research questions to pursue and considerations for research designs to answer these questions. AHRQ will distribute this list widely and a full report will be posted on their website.
- Thank you for your participation. We look forward to getting your feedback on the survey. You should look for that in your inbox sometime in March. And, please do not hesitate to call or e-mail should you think of additional areas that we should include or if you have any questions.