# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
CER: comparative effectiveness review
COI: conflict of interest
EPC: Evidence-based Practice Center
FRN: future research needs
IMT: inspiratory muscle training
IRB: Institutional Review Board
KI: Key Informant
NIH: National Institutes of Health
PICO: Populations, Interventions, Comparators, Outcomes
RCT: randomized controlled trial
RQ: research question
TEP: Technical Expert Panel