# Results

## Research Needs

As stated in the Methods section, we had the Stakeholder Panel rank the research gaps and generate research questions online prior to the second and third teleconference calls, respectively. The results of the first survey ranking the importance of these evidence gaps are found in Appendix E, and those of the second survey ranking the importance of research questions are found in Appendix F.

A total of 18 evidence gaps were identified through a combination of the CER findings and conversations with the Stakeholder Panel (Appendix E). These gaps were grouped based on the three Key Questions addressed in the CER (i.e., prevention, antibiotic treatments, and adjunctive nonstandard interventions). The response rate was 100 percent (n=9); 16 (of 18) evidence gaps received votes (Appendix E).

The EPC generated the final ranking of evidence gaps taking all Stakeholder Panel comments into account. Several top-ranked gaps (Appendix E) brought forth through Panel discussions related to research into the epidemiology of CDI and basic science to understand the microbiology. Increased understanding of the basic science underlying CDI (and Clostridium difficile) was brought forth by the Stakeholder Panel to be critical for informing prevention efforts. Panel members highlighted the need for future studies on these aspects including further understanding of the gut microbiome, mapping of CDI, and modes of transmission of Clostridium difficile. These research areas related to the basic science and epidemiology of CDI were considered outside the original scope of the CER (i.e., the literature in these areas was not submitted to any systematic analysis) and thus not prioritized with the remaining evidence gaps for this Future Research Needs project. The evidence gaps outside the scope are highlighted in Appendix E.

The Stakeholder Panel also discussed the implications of the published studies and ongoing trials identified through the literature search update; these were not considered ‘groundbreaking’ from a prevention and treatment standpoint to impact the list of evidence gaps. Panel members proposed regrouping and rearrangement of the top-ranked evidence gaps as some of these gaps addressed similar issues. The final four research gaps are stated in Table 4.

Table 4 Prioritized list of evidence gaps

1. Effectiveness and harms of single and/or multi-component prevention strategies for CDI; 2. Effectiveness and harms of different strategies for recurrent CDI treatment and prevention; 3. Effectiveness and harms of antibiotic treatments for first episode of CDI; 4. Effectiveness and harms of fecal transplantation for management of CDI

The prioritized list of evidence gaps, accompanied by preliminary research questions drafted by the EPC across each gap, was submitted for feedback to panel members via email following the second Stakeholder Panel call. Following this feedback, the second survey of research questions was submitted to Panel members for ranking prior to the third Stakeholder Panel call. As with the evidence gaps, the research questions were presented in a random order for the survey. The response rate was 100 percent (n=9); all questions received votes (Appendix F). Panel members discussed the importance and usefulness of future studies on the top-ranked questions based on the voting results at the third Stakeholder Panel call; eight (of 9) members were present on the third Stakeholder Panel call and an alternate call was held with one member unable to participate on this call. Panel members reiterated the need for more basic epidemiologic data to address these questions especially for those related to prevention strategies. There was discussion on the appropriate threshold with respect to a short-list of research questions; further combining some of the overlapping topics on the list into key categories would be of benefit in this regard.

Panel members discussed the different weights given to the selection criteria when prioritizing research questions (e.g., potential health impact vs. feasibility), and other aspects including the role of entities which may fund this research to the short-list of research questions (e.g., likelihood of future studies for each of the research questions being sponsored by industry as opposed to funding by Federal or other non-profit sources). There also was further discussion for any redundancies around the research questions in light of the respective ongoing trials. Panel members reviewed the results of the literature search update; MEDLINE® yielded no new studies, neither did The Cochrane Library, yet 35 studies emerged from ClinicalTrials.gov that fell into this short update period. After careful review 15 studies appeared to address five (of 11) research questions (Appendix F). These discussions formed the basis for the final prioritized list of seven research questions below (Table 5; in order of priority).

Table 5 Prioritized list of research questions

1. What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings?; 2. What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI?; 3. What is the comparative effectiveness of different treatment options for recurrent CDI?; 4. What are the factors/determinants that make for better recurrence prevention for CDI?; 5. What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI?; 6. What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings?; 7. To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates?

The final prioritized list of evidence gaps and research questions with details (PICOTS information and considerations of pros and cons of various research designs (developed after the second round of ranking) are stated in Table 6. The specific research projects to address each evidence gap and research questions are described in more detail in the following section.

Table 6 Prioritized list of evidence gaps and research questions

Evidence Gap | Research Question | Population | Intervention | Comparator | Outcomes | Timing | Setting
Effectiveness and harms of single and/or multi-component prevention strategies for CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Not the right information (results not applicable to setting of interest). | [underlined: 1.1] What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings? [underlined: 1.2] What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings? | Hospital inpatients, ambulatory care patients, residents of any healthcare facility without symptoms/diagnosis of CDI on admission | Novel strategy (+ standard care) e.g., intensified environmental cleaning | Standard care alone | Primary: change in acquisition incidence of CDI, adverse events; secondary: changes in antibiotic usage, antimicrobial resistance, length of stay, barriers to implementation, mortality | Defined a priori | Hospital, ambulatory care, nursing home
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.1] What is the comparative effectiveness of different treatment options for recurrent CDI? | Patients with laboratory confirmed recurrence of CDI of any disease severity | Novel therapy e.g., monoclonal antibody, drug ACT-179811 | Different treatment options (standard care) | Primary: initial response to therapy (e.g., mean days to resolution of diarrhea, clearance of toxin, persistence of the organism), harms; secondary: recent antibiotic history, sustained response, mortality. | Duration of followup of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence (for prospective studies) | Hospital, outpatient clinics
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.2] What are the factors/determinants that make for better recurrence prevention for CDI? | The PICOTS on this question will depend on study question and design
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.3] To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates? | Patients being treated for CDI or who have completed CDI treatment | Concomitant antibiotic administered either during or after CDI therapy | No concomitant antibiotic or an alternative concomitant antibiotic | Initial response rate and sustained response rate for CDI, harms, time to initial response, duration of CDI therapy, mortality | A few weeks | Any healthcare setting
Effectiveness and harms of antibiotic treatments for first episode of CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Not the right information (optimal/most important outcomes not addressed) | [underlined: 3.1] What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI? | Patients diagnosed with CDI | Novel therapy e.g., modified release metronidazole, fixadomycin with vancomycin | Vancomycin or metronidazole | Primary: Initial response e.g. resolution of diarrhea at end of treatment (~10 days), harms, recent antibiotic history; secondary: sustained response (i.e. initial response without recurrence), mean days to resolution of diarrhea, death | Variable but likely a few weeks | Hospital, nursing home, long-term care facility, community
Effectiveness and harms of fecal transplantation for management of CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Information at Risk of Bias (major methodological limitations in studies) | [underlined: 4.1] What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI? | Patients with laboratory confirmed recurrence of CDI of any disease severity | Fecal transplantation | Vancomycin or metronidazole | Primary-initial response to therapy (e.g., mean days to resolution of diarrhea, clearance of toxin, persistence of the organism), harms; secondary: recent antibiotic history, sustained response, mortality. | Duration of followup of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence (for prospective studies) | Hospital, outpatient clinics

### Research Question Number 1.1

What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings?

### Research Question Number 1.2

What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings?

The study design evaluations for research questions 1.1 and 1.2 were combined as they would require the same design and face similar challenges (Table 7). Based on the CER, the focus of these questions is on the contribution of preventive strategies aimed at interrupting transmission of Clostridium difficile and reducing susceptibility to CDI in non-outbreak settings; this would include non-acute care facilities, which is an understudied setting. Onset in the majority of CDI cases occurs outside of the hospital setting, as relatively few cases can be traced back to other CDI cases in the hospital. Results may need to be stratified by preintervention Clostridium difficile acquisition incidence, as CDI incidence may be too low to use. Prevention measures may be evaluated individually or as bundled strategies, and may need to account for other institutional infection control practices already in place (referred to as standard care in Table 7), using higher quality comparative effectiveness research approaches.10 Information on barriers to implementation and sustainability of such programs should be obtained.

Table 7 Study design evaluations for Research Questions 1.1 and 1.2

Study design considerations | Randomized controlled trial (RCT) | Quasi-experimental: before-after study (variations) | Modeling
Description of design | Individuals or groups randomly assigned to receive novel strategy or standard care. Patients and potentially staff are followed during implementation for incidence of CDI and other adverse events. Longer follow-up post implementation may be required if sustainability is a desired outcome. Cluster RCTs that randomize at a hospital or ward level may be more suitable for population-level strategies in non-outbreak settings when outcomes for individuals from a given unit are not independent. If pooling data across institutions is required, consensus on outcome measures, minimum datasets and follow-up periods would be needed. | Incidence of CDI compared in a group of individuals before and after exposure to the preventive strategy. Investigator controls timing of measurement(s) and variables (e.g. baseline disease severity) measured, but not all intervention variables are in the control of the investigator. If pooling data across institutions is required, consensus on outcome measures, minimum datasets and follow-up periods would be needed. | Simulation model developed and validated to assess the value of individual strategies or individual components of bundled strategies across a range of populations, settings and conditions. Use of agent based modeling for tracking CD transmission would allow for assessing the impact of different interventions.
Advantages of study design for producing a valid result | Best method to control for selection bias but potentially at the cost of generalizability. It should produce the most valid results. Requires planning to balance baseline characteristics and sample size considerations. | Simple design with generalizable results. May be best option if randomization is not possible. Highly susceptible to confounding variables, regression to the mean and maturation effects. Internal validity may be strengthened by use of a concurrent nonrandomized comparison group that is not exposed to the preventive strategy, by multiple pre-intervention observations and by replication in different groups at multiple times. These studies must have adequate statistical methods to control for confounding and secular trend, otherwise no causal inference can be made. | May be the best option to use when questions cannot be addressed using conventional clinical trial methods or existing data analysis. May inform and help focus future clinical trials and data collection. Models can be tailored to multiple end users/perspectives, conditions and settings to enhance generalizability of findings and to help target interventions (different situations may call for different interventions). Other forms of modeling (e.g. compartment based, decision tree, etc.) can be informative but will require more assumptions and thus greater variability with less confidence in the results.
Resource use, size and duration | Depending on the strategy and desired effect size, costs, sample size and staff time needed for recruitment and implementation could be high. Recruitment of individuals or unit “clusters” willing to be randomized may be a constraint on sample size. Duration likely to be brief which may keep costs down, but if sustainability is a desired outcome, then longer follow-up will be required. | Generally less resource intensive than an experimental design. Otherwise, size and duration issues would be similar to RCT. | May require substantial personnel time but is generally less resource intensive than primary studies. Once agent based modeling identifies the transmission chains of CD, other modeling studies (e.g. decision tree) can be performed, but may require primary data collection to inform components if reliable estimates cannot be obtained from the literature, empiric studies or experts.
Ethical, legal, and social issues | Ethical issues are moderate as the effectiveness may be uncertain. For cluster RCTs, a waiver of informed consent would be required. Otherwise a cluster RCT would not be possible if individuals have the ability to drop out. Legal mandates or clinical culture may impede randomization to novel interventions or supersede trial objectives. | Ethical issues are moderate as the effectiveness may be uncertain. A waiver of informed consent may be required if comparisons are at a unit level. Legal mandates or clinical culture may supersede trial objectives. | Ethical issues are moderate. To obtain data needed to do agent based modeling, ideally would need waiver of informed consent would be needed, as missed CD carriers could significantly bias the data.
Availability of data or ability to recruit | Cluster RCTs require collaborative network of sites willing to participate. Strategies implemented at the unit level require participation of all individuals within that unit, which could affect recruitment. | Recruitment is generally feasible, particularly where randomization is unacceptable. Strategies implemented at the unit level require participation of all individuals within that unit, which could affect recruitment. | Data would be obtained primarily from published sources, proprietary institutional databases, and expert opinion. The enrollment or consent process may be challenging particularly among sicker patients. As above, a waiver of informed consent would be needed, as missed CD carriers could significantly bias the data.

### Research Question Number 2.1

What is the comparative effectiveness of different treatment options for recurrent CDI? The study design evaluations for this question was combined with research question number 4.1 as they would require the same design and face similar challenges. The considerations associated with the study designs addressing this question are discussed under research question number 4.1 below.

### Research Question Number 2.2

What are the factors/determinants that make for better recurrence prevention for CDI?

Considerations: Based on Stakeholder Panel discussions, there was uncertainty on how best to address this question. Significant research exists on factors associated with recurrence, except for what can be associated with the first treatment. This question could possibly be combined with other questions of treatment effectiveness and look for less-studied hypothesized risk factors (e.g., procalcitonin in the stool or spore counts) as well as some known factors. Definitions of a number of patient characteristics and outcomes would need to be formulated a priori. Any study type must include a comparison of harms and should attempt to stratify by disease severity with adequate sample sizes to detect meaningful differences (Table 8).

Table 8 Study design evaluations for Research Question 2.2

Study design considerations | Randomized controlled trial (RCT) | Prospective cohort study | Nested case-control study | Case-control study
Description of design | Individuals with CDI randomly assigned to novel therapy versus standard therapy and followed prospectively for a defined period. Data gathered on risk factors of interest. | Individuals with CDI non-randomly assigned treatment by physician and followed prospectively for a defined period. Data gathered on effectiveness and risk factors of interest. | A sampling of patients who have been treated for CDI and developed recurrence (cases) or did not develop recurrence (controls) are included from a prospective cohort and followed prospectively for a defined period. Data on risk factors collected retrospectively. May be nested within prospective studies of treatment effectiveness. | Patients who have been treated for CDI and developed recurrence (cases) or did not develop recurrence (controls) are included. Data on treatment exposure and risk factors of interest collected retrospectively.
Advantages of study design for producing a valid result | This design is feasible and should provide the most valid results, as important characteristics should be balanced between the two groups. | May be optimal if random assignment is impractical. Less valid than RCT as baseline characteristics may not be balanced, but may be more generalizable. | Usually more valid than case-control study but balance of baseline characteristics is largely dependent on the original cohort. | Relatively quick to collect data, but has multiple threats to validity. Sample should accurately reflect population of interest and sampling method should be clearly described.
Resource use, size and duration | Likely to require substantial resources to collect epidemiological data of interest and to recruit adequate sample sizes, and multiple sites may be needed. Duration of follow-up of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence. | Resources and duration would be similar to RCTs. | Resources are low as it uses existing data and fewer subjects. Duration may be shorter than prospective studies. | Same as nested case control study.
Ethical, legal, and social issues | Ethical issues are high, as the effectiveness of one or more interventions is uncertain. Enrollment and consent of critically ill patients could be an issue. | Ethical issues are lower than with RCT because of nonrandomized assignment. | Minimal since data are already collected. | Minimal since data are already collected.
Availability of data or ability to recruit | Recruitment could be an issue due to willingness to be randomized. Recruitment may be slow at any one site, and multiple centers may be needed. | This design is generally more acceptable to participants. Recruitment issues are similar to RCT. | Availability of data should be high, since study samples data already collected. | Same as nested case control study.

### Research Question Number 2.3

To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates?

Considerations: Studies should include sufficient correction for confounders such as severe underlying disease, advanced age, etc. The Stakeholder Panel emphasized the need for further retrospective analyses to look at the epidemiology of the population before hospital admission (e.g., examine the data with these larger numbers of patients to determine some of the factors for poor outcomes, for concomitant antibiotics, and to determine which patients will do poorly with their infection, the relationship between number of days on antibiotic therapy and relapse rates.) However, epidemiological studies were not addressed in the scope of the CER, yet such data would inform this question and others (Table 9).

Table 9 Study design evaluations for Research Question 2.3

Study design considerations | Prospective cohort | Retrospective cohort study | Modeling
Description of design | Patients classified according to whether they are on concomitant therapy either during or after CDI treatment and followed prospectively for a defined period. Data on desired outcomes are compared. | Patients who were treated for CDI are classified according to concomitant antibiotic status and followed to a pre-specified endpoint. Desired outcomes between intervention and comparison groups are compared. | Simulation model designed to assess impact of concomitant antibiotics for a range of subpopulations, settings and conditions. May be used to define factors (covariates) impacting response rate and other outcomes (e.g., role of concomitant antibiotics, role of carriers, reducing antibiotics by X amount, age, severity of underlying diseases)
Advantages of study design for producing a valid result | This design may be optimal and should provide the most valid results, as randomization would not be feasible. Baseline clinical characteristics (e.g. indication for treatment, disease severity) may not be balanced between the two groups. Consensus on definitions of a number of patient characteristics (e.g. disease severity) and outcomes would be needed to enhance generalizability to a non-breakout setting. | Uses existing data, but design is subject to selection bias and imbalance of baseline clinical characteristics. Generalizability may be impacted by the population studied. | May be the best option to use when questions cannot be addressed using conventional clinical trial methods. May inform and help focus future clinical trials. Models can be tailored to multiple end users, conditions and settings to enhance generalizability of findings.
Resource use, size and duration | Willingness to participate is high since patients would not be randomized. Likely to require substantial resources to recruit adequate sample sizes, as multiple sites may be needed. Duration of follow-up would likely be short (a few weeks). | Duration is generally shorter than a prospective analysis. Sample size may need to be large for subgroup analyses stratified by disease severity, age, et cetera. | May require substantial personnel time but is generally less resource intensive than primary studies. May require some primary data collection to inform components of the analysis if reliable estimates cannot be obtained from the literature or experts.
Ethical, legal, and social issues | Ethical issues are low, since patients/providers select treatment. May require a waiver for informed consent for population-level analyses, as drop outs would be an issue. | No major legal or ethical issues. | Ethical issues are low. Few administration approvals would be needed to access confidential information. If primary data collection is needed, human subjects protections will be needed for enrollment/consent.
Availability of data or ability to recruit | Recruitment may be slow at any one site, and multiple centers may be needed. Definitions of a number of patient characteristics and outcomes would need to be defined a priori. | No major issues other than obtaining approval for access to data, as the data have been collected. Heterogeneity of definitions of patient characteristics and outcomes could be a problem. | Data would be obtained primarily from published sources, proprietary institutional databases, and expert opinion, so patient recruitment issues would not exist. If primary data collection is needed to inform elements of the model, the enrollment or consent process may be challenging particularly among sicker patients.

### Research Question Number 3.1

What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI?

Considerations: Based on the CER, the focus of this question is on comparing the effectiveness of novel antibiotics to the most frequently used antibiotics (vancomycin and metronidazole) for treating an initial episode of CDI, using higher quality comparative effectiveness research approaches. Any study type must include a comparison of harms and attempt to stratify by baseline disease severity with adequate sample sizes to detect meaningful differences. No data were available to assess the importance of general patient characteristics or the strain of organism on the effectiveness of an antimicrobial and it is unclear at this time how clinically relevant it would be to collect these data (Table 10).

Table 10 Study design evaluations for Research Question 3.1

Study design considerations | Randomized controlled trial (RCT) | Nonrandomized comparative study | Retrospective cohort
Description of design | Individuals with CDI randomly assigned to novel therapy versus standard therapy and followed prospectively for a defined period. Data collected on harms, initial clinical cure, clinical recurrence, mean days to resolution of diarrhea and death. | Individuals diagnosed with CDI are assigned to novel therapy or standard care based on physician choice or purposive sampling and followed prospectively for a defined period. Data collected on harms, initial clinical cure, clinical recurrence, mean days to resolution of diarrhea and death. | Individuals with CDI who were treated with novel therapy or standard care are included and followed for a specified period of time. Data collected on recent antibiotic history, potential risk factors, harms, initial clinical cure, clinical recurrence, mean days to resolution of diarrhea and death.
Advantages of study design for producing a valid result | This design is feasible and should provide the most valid results, as clinical characteristics (e.g. indication for treatment, disease severity) should be balanced between the two groups. Consensus would be needed on definitions and reporting of outcomes, and a clinically relevant definition of disease severity to enhance generalizability to a non-breakout setting. | Design is susceptible to selection bias, but may be an optimal design if required sample size is large and the patient or their practitioner finds random assignment unacceptable. Statistical techniques may partially control for confounders. | Uses available data sources. Significant risk of selection bias and incomplete data. Generalizability will depend on population sample. May produce less valid results than an RCT, but may be a more feasible way of estimating effectiveness of new drugs for which some evidence of safety and efficacy exists.
Resource use, size and duration | Recruitment could be an issue due to willingness to be randomized. Likely to require substantial resources to recruit adequate sample sizes. Multiple sites may be needed to reach adequate sample sizes. Duration of follow-up of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence, as late recurrences after 8 weeks are rare. | Likely to require similar resources as RCT. Multiple sites may be needed to reach adequate sample sizes. Duration of follow-up would be short (a few weeks). | Less resource intensive and shorter than a prospective study. There may be costs associated with using data.
Ethical, legal, and social issues | Ethical issues are moderate, as the effectiveness of the intervention is uncertain, but the perception may be that patient safety is being compromised by withholding an intervention considered standard care while exposing a patient to an uncertain intervention. Enrollment and consent of critically ill patients could be an issue. | Ethical issues are lower because assignment is not random, but the effectiveness of the novel intervention is still uncertain. Enrollment and consent of critically ill patients could be an issue. | No major ethical or legal issues, unless multiple databases are linked then confidentiality and privacy issues may require patient approvals.
Availability of data or ability to recruit | Recruitment may be slow at any one site, and multiple centers may be needed. Definitions of a number of patient characteristics and outcomes would need to be formulated a priori. | Generally more acceptable to potential subjects than random assignment. Severity of patient condition and practitioner preferences may affect consent and enrollment. | May require multiple sites to obtain adequate sample sizes for subgroup analyses and agreement with proprietors of data sources. Obtaining clinical data outside the hospital may be difficult. Lack of uniformity in definition of severity and in reporting of outcomes and adverse events may impede data collection.

### Research Question Number 4.1

What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI? The study design evaluations for this question was combined with research question number 2.1 as they would require the same design and face similar challenges.

Considerations: Based on the CER, these questions address the effectiveness of various treatment options, including antibiotics and nonstandard fecal transplantation as adjunctive or alternative therapy, compared with the most frequently used antibiotics (vancomycin and metronidazole) for treating recurrence of CDI, using higher quality comparative effectiveness research approaches. Both questions can be addressed using similar study designs. The CER did not identify any evidence for comparative effectiveness stratified by general patient characteristics such as age, gender, or treatment setting. No data were available to assess the importance of general patient characteristics or the strain of organism on the effectiveness of an antimicrobial and it is unclear at this time how clinically relevant it would be to collect these data. Consensus will be needed on frequency and duration of novel treatment, when to stop treatment, duration of follow-up, and definitions of initial cure, recurrence, disease severity and outcomes. Any study type must include a comparison of harms and should attempt to stratify by disease severity with adequate sample sizes to detect meaningful differences (Table 11).

Table 11 Study design evaluations for Research Questions 2.1 and 4.1

Study design considerations | Randomized controlled trial (RCT) | Prospective cohort | Retrospective cohort
Description of design | Individuals with CDI recurrence diagnosed with toxin test randomly assigned to novel therapy versus standard therapy and followed prospectively for a defined period. May include a crossover design if first assigned treatment fails. Data collected on outcomes. | Individuals with CDI recurrence are assigned to novel therapy or standard care by physician and followed prospectively for a defined period. Data collected on outcomes. | Individuals with CDI recurrence who were treated with novel therapy or standard care are included and followed for a specified period of time. Data collected on outcomes.
Advantages of study design for producing a valid result | This design is feasible and should provide the most valid results, as clinical characteristics should be balanced between the two groups. Crossover design may be more acceptable to physician and patient, reduce influence of covariate imbalance, and improve study efficiency, but treatment order may affect results. | Design is susceptible to selection bias, but may be an optimal design if required sample size is large and the patient or their practitioner finds random assignment unacceptable. Statistical techniques may partially control for confounders. | Uses available data sources. Significant risk of selection bias and incomplete data. Generalizability will depend on population sample. May produce less valid results than an RCT, but may be a more feasible way of estimating effectiveness of novel treatments for which some evidence of safety and efficacy may exist.
Resource use, size and duration | Recruitment could be an issue due to willingness to be randomized. Multiple sites may be needed to reach adequate sample sizes, but crossover design may help reduce numbers needed. | Likely to require similar resources as RCT. Multiple sites may be needed to reach adequate sample sizes. Duration of follow-up would be same as RCT. | Less resource intensive and shorter than a prospective study. There may be costs associated with using data.
Ethical, legal, and social issues | Ethical issues are moderate, as the effectiveness of the novel intervention is uncertain, yet standard care has also been ineffective. Patients’ attitudes toward novel therapies may inhibit enrollment; alternatively they may be open to new, “natural” options. | Ethical and social issues are similar to RCT. | No major ethical or legal issues, unless multiple databases are linked then confidentiality and privacy issues may require patient approvals.
Availability of data or ability to recruit | Recruitment may be slow at any one site, and multiple centers may be needed. May require significant education of patients and physicians. Definitions of a number of patient characteristics and outcomes would need to be formulated a priori. | Similar to RCT, but may be more acceptable to potential subjects and practitioners than random assignment. Severity of patient condition and practitioner preferences may affect consent and enrollment. | May require multiple sites to obtain adequate sample sizes for subgroup analyses and agreement with proprietors of data sources. Obtaining clinical data outside the hospital setting may be difficult. Lack of uniformity in patient variables and in reporting of outcomes and adverse events may impede data collection.