# References

1 Butler M, Bliss D, Drekonja D, et al. Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection, Comparative Effectiveness Review No. 31. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-02-0009). AHRQ Publication No. 11(12)-EHC051-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2011.
2 Bartlett JG, Chang TW, Gurwith M, et al. Antibiotic-associated pseudomembranous colitis due to toxin-producing clostridia. N Engl J Med. 1978;298:531-534. [pmid: 625309].
3 Riggs MM, Sethi AK, Zabarsky TF, et al. Asymptomatic carriers are a potential source for transmission of epidemic and nonepidemic Clostridium difficile strains among long-term care facility residents. Clin Infect Dis. 2007;45:992-998. [pmid: 17879913].
4 Kelly CP, LaMont JT. Clostridium difficile — more difficult than ever. N Engl J Med. 2008;359:1932-1940. [pmid: 18971494].
5 Pépin J, Valiquette L, Cossette B. Mortality attributable to nosocomial Clostridium difficile-associated disease during an epidemic caused by a hypervirulent strain in Quebec. CMAJ. 2005;173(9):1037-1042. [pmid: 16179431].
6 Mauger Rothenberg B, Marbella A, Belinson SE, et al. Future Research Needs for Comparative Effectiveness of Treatments for Localized Prostate Cancer, Future Research Needs Paper No. 4. (Prepared by Blue Cross and Blue Shield Association, Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I). AHRQ Publication No. 10-EHC072-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010.
7 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. Journal of Clinical Epidemiology. 2010;63:491-501. [pmid: 19540721].
8 Carey T, Sanders GD, Viswanathan M, Trikalinos TA, Kato E, Chang S. Framework for Considering Study Designs for Future Research Needs, Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012.
9 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews, Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I). AHRQ Publication No 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011.
10 Perencevich EN, Lautenbach E. Infection prevention and comparative effectiveness research. JAMA. 2011;305(14):1482-1483. [pmid: 21486981].