# Methods

## Identification of Evidence Gaps

Figure 2 outlines the process steps of this Future Research Needs project. The details are described in the text. First, evidence gaps were identified through the Minnesota EPC CER. After the CER was published, the literature search was updated and ClinicalTrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified and through and iterative process the gaps were shared with and refined by these stakeholders (see section on engagement of stakeholders, researchers and funders). A group of nine stakeholders (Stakeholder Panel) representing diverse perspectives was formed; this group prioritized the refined evidence gaps, and generated research questions (see sections on criteria for prioritization, and research question development). Gaps were prioritized through the Web using the SurveyMonkey® Web site. Finally, the exploration of various research designs was conducted by the EPC. Details of these steps follow.

Figure 2 Process flow diagram

Figure 2 outlines the 11-step process steps of this future research needs project. First, evidence gaps were identified through the Minnesota EPC CER. After the CER was published, the literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified and through and iterative process the gaps were shared with and refined by these stakeholders. A group of nine stakeholders (Stakeholder Panel (SP)) representing diverse perspectives was formed; this group prioritized the refined evidence gaps, and generated research questions. Gaps were prioritized through the Web using the SurveyMonkey® Web site. Finally, the exploration of various research designs was conducted by the EPC. The details are described in the text.

## Project Scope

The project team held multiple meetings to discuss the Future Research Needs project scope including dialogue with the lead investigator of the CER. Through these discussions, the project team focused the project on CDI prevention and treatment, including antibiotic therapy, immunotherapy, and reconstitution or manipulation of the gut microflora (i.e., probiotics, fecal transplant, etc.), and other novel and “nonstandard” adjunctive interventions. This Future Research Needs project addresses the appropriateness and effectiveness of varied preventive and therapeutic interventions are in patient subgroups. Although different diagnostic methods for toxigenic Clostridium difficile were evaluated in the CER, diagnostic methods were not included in this project primarily because polymerase chain reaction testing is rapidly becoming the standard diagnostic test for the infection.

## Literature Search Update

To identify published and ongoing studies addressing the CDI evidence gaps, we conducted searches using MEDLINE® (via PubMed®), the Cochrane Library, and the ClinicalTrials.gov databases. The search captured studies published since January 2012 for the evidence gaps identified in the CER. As the time frame was short and retrieval was expected to be quite small, an initial search was undertaken for all ongoing CDI studies (Appendix B).

## Criteria for Prioritization

In criteria for prioritization, we drew on our experience from a Future Research Needs project for localized prostate cancer,6 in which the Effective Health Care (EHC) Program Selection Criteria were modified to be applicable to primary research rather than to systematic reviews of original research.7 The criteria were used to prioritize gaps and research questions (Table 3). The modified EHC Program Selection Criteria were distributed to panel members each time they were asked to prioritize evidence gaps or research questions. Prioritization of study designs was handled by the EPC in accordance with the recent FRN methods report by AHRQ.8 The Stakeholder Panel provided insight into how future research agendas and proposed studies to address gaps fit within these prespecified criteria.

Table 3 Prioritization criteria for evidence gaps and proposed research studies

Category | Criterion
Current importance | - Incorporates both clinical benefits and harms; - Represents important variation in clinical care due to controversy/uncertainty regarding appropriate care; - Addresses high costs to consumers, patients, health-care systems, or payers; - Utility of available evidence limited by changes in practice, for example disease detection
Potential for significant health impact | - Potential for significant health impact:; ○ To improve [underlined: health outcomes]; ○ To reduce [underlined: significant variation] related to quality of care; ○ To reduce [underlined: unnecessary burden] on those with health-care problems; - Potential for significant economic impact, reducing unnecessary or excessive costs.; - Potential for evidence-based change.; - Potential risk from inaction, for example lack of evidence for decisionmaking produces unintended harms; - Addresses inequities, vulnerable populations, patient subgroups with differential impact (e.g., by age)
Incremental value | - Adds useful new information to existing portfolio of research on topic OR; - Validates existing research when body of evidence is scant.
Feasibility | Factors to be considered:; - Interest among researchers; - Duration; - Cost; - Methodological complexity (e.g., do existing methods need to be refined?); - Implementation difficulty; - Facilitating factors; - Potential funders

## Methods for Ranking Research Gaps

Evidence gaps were ranked via the SurveyMonkey® Web site. The Stakeholder Panel was sent a link to the Web site where they ranked the research gaps from 1 to 5 and generated research questions for each gap. The survey allowed each rank to be used only once. Points were assigned to each gap: 1 point for a ranking of fifth, up to 5 points for a ranking of first. The gap with the largest number of points was assigned the highest priority. The gaps were presented in a random order for the survey. The comments received from the Stakeholder Panel were reviewed by EPC staff and incorporated where necessary. In addition to the modified EHC Program Selection Criteria, special attention was paid to where evidence gaps overlapped with existing research. The reasons for each evidence gap were categorized based on a classification scheme created by the Johns Hopkins University EPC on behalf of AHRQ.9

## Engagement of Stakeholders, Researchers, Funders

Central to the methodology of this report was the use of the Stakeholder Panel to identify and prioritize evidence gaps. A single multidisciplinary Stakeholder Panel was convened to provide input on this project. The Panel included individuals interested in comparative effectiveness research and knowledgeable about current research on CDI. They consisted of nine participants (including the lead investigator of the CER) representing diverse perspectives, including methodological/research expertise, clinical experience (from infectious diseases, epidemiology, gastroenterology), and patient and payer representation. The Stakeholder Panel brought forth specific expertise on prevention and treatment of CDI, including antibiotic therapy, immunotherapy, and reconstitution or manipulation of the gut microflora (e.g., fecal transplantation, probiotics).

The Stakeholder Panel was asked to recommend important studies published since the Minnesota EPC completed the CER,1 revise and prioritize the evidence gaps listed in the CER and gathered throughout this project, and develop and prioritize a list of potential research questions to address those gaps. As proscribed by AHRQ, conflict of interest forms were completed by all panel members and staff on this project. The multidisciplinary character of the Stakeholder Panel and their varied affiliations enriched the process.

The Stakeholder Panel was asked to participate in three conference calls (1 hour each) over the project duration, and some interim communications by email. In addition, a brief introductory call (30 minutes) was scheduled separately with each individual member, to provide an overview of the project, to discuss the role of the Stakeholder Panel, and to solicit preliminary suggestions on further evidence gaps. The First Call was held on February 7, 2012. During this call, the members were asked to review the preliminary list of evidence gaps. This list was a synthesis of evidence gaps from the CER, those proposed by panel members during the individual introductory calls, and results of the literature search update. Following the first call, the Stakeholder Panel members were asked to rank, via an online survey, their top 5 evidence gaps from 1 to 5 with 1 having the highest priority and 5 the lowest. Panel members rated these evidence gaps based on revised EHC program selection criteria (Appendix C). The Second Call was scheduled on February 28, 2012. During the second call, Stakeholder Panel members were invited to review the prioritized list of research gaps and “brainstorm” research questions to address each evidence gap.

The Third Call was convened on March 30, 2012 for prioritization of research questions. A list of potential research questions were sent to members via electronic mail prior to this teleconference call. The Stakeholder Panel was asked to prioritize the research questions via an online survey instrument (using SurveyMonkey™) similar to that used for selection of evidence gaps. As with the online survey for evidence gaps, members were asked to rank their top 5 research questions from 1 to 5 with 1 having the highest priority and 5 the lowest (Appendix D). The project team collated the “votes” and reported the results at the third Panel meeting held via teleconference. The meeting participants reviewed the results and further discuss the importance of the research questions to patients and clinical decisionmaking. These discussions formed the basis for the final prioritized list of research questions submitted to AHRQ. Alternate calls were scheduled as necessary with members who were unable to participate during the panel calls, in accordance with the collective preferences of the panel members and the project team. All teleconference call materials were distributed a few days prior to scheduled calls. To enhance public engagement, AHRQ will solicit broader input on this document by making it available for public input, which will be incorporated and reflected in the final report.

## Research Question Development and Study Design Considerations

Key research questions for each evidence gap were generated through an online survey instrument and discussions by the Stakeholder Panel (discussed previously). The project team compiled a final list of research questions taking the feedback of the Panel into consideration. The research questions were characterized using the PICOTS framework using the population (P), intervention (I), comparison (C), outcomes (O), timing (T), and setting (S). The project team evaluated potential study designs to address each of the key research questions. This approach is consistent with the guidance published by AHRQ.8 The appropriateness of any one study design to address an evidence gap was further evaluated using the following criteria:

- Advantages of the study design for producing a valid result
- Resource use, size, and duration
- Ethical, legal, and social issues
- Availability of data or ability to recruit

The project team relied on this framework8 as a guide during discussions of the least biased study design that was likely to be feasible and affordable. Public comments received after the document is posted will be incorporated into the final report.