# Introduction

## Background

### Context

Clostridium difficile infection (CDI) is a serious healthcare-associated infection and a growing health care problem, especially with the emergence of more virulent strains in the early 2000s.1Clostridium difficile was first recognized as having the ability to cause pseudomembranous colitis in the late 1970s.2 CDI is now the most common cause of nosocomial infectious diarrhea. Asymptomatic colonization in healthy adults has been observed in only 3 percent of persons, while the prevalence of such colonization among residents in long-term-care facilities approaches 50 percent.3 Individuals colonized with Clostridium difficile serve as a reservoir for infection by contaminating the environment with Clostridium difficile spores, thus leading to the spread of the organism on the hands of health care workers or via use of medical equipment. CDI is increasing in incidence and, in all likelihood, severity. The number of cases diagnosed among patients discharged from hospitals increased from 31 per 100,000 persons in 1996 to 84 per 100,000 persons in 2005.^4^ Infection due to a relatively new strain of Clostridium difficile, termed “North American pulsed-field gel electrophoresis type 1” (NAP1), is felt to be at least partially responsible for this increased incidence of CDI as well as for the increased severity of clinical illness. The NAP1 strain is capable of producing more than 15 times the quantity of both toxins A and B, which are directly responsible for the damage to the intestinal tract of infected patients. Hence, CDI is not only now more common, but also more severe, leading to an attributable mortality of up to 16 percent of all deaths.5

A comparative effectiveness review (CER) was prepared by the Minnesota Evidence-based Practice Center (EPC) on Comparative Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection (December 2011).1 The purpose of the CER was to provide an overarching assessment of the evidence for comparing the accuracy of diagnostic tests and the effectiveness of prevention and treatment interventions on initial and recurrent CDI-related patient outcomes in adults. Key informants, provided input to the EPC on the scope of the CER, agreed that its greatest contribution to the field could be to have an independent organization provide a comprehensive review of the major concerns of the field for both clinicians and researchers.1

The major impetus underlying the SR was a concern about the presence of clinical disease, not asymptomatic carriage of the Clostridium difficile organism.1 Molecular epidemiological studies whose main purpose was to identify the strains of Clostridium difficile present in the population were outside the scope of the CER. The CER focused on adult patients as they, particularly elderly adults, carry the most of the morbidity and mortality burden.1

The CER addressed the following Key Questions (KQs):

1. How do different methods for detection of toxigenic Clostridium difficile to assist with diagnosis of CDI compare in their sensitivity and specificity?
  a. Do the differences in performance measures vary with sample characteristics?
2. What are effective prevention strategies?
  a. What is the effectiveness of current prevention strategies?
  b. What are the harms associated with prevention strategies?
  c. How sustainable are prevention practices in health care (outpatient, hospital inpatient, extended care) and community settings?
3. What are the comparative effectiveness and harms of different antibiotic treatments?
  a. Does effectiveness vary by disease severity or strain?
  b. Does effectiveness vary by patient characteristics: age, gender, comorbidity, hospital-versus community-acquired setting?
  c. How do prevention and treatment of CDI affect resistance of other pathogens?
4. What are the effectiveness and harms of nonstandard adjunctive interventions?
  a. In patients with relapse/recurrent CDI?1

Limited high-quality evidence was available to support the diagnostic, preventive, and treatment practices for CDI carried out by providers in hospital, long-term care, and outpatient settings.1 The KQ s and summary of results from the CER are presented in Table 1 below. Appendix A provides further details on the findings presented in the CER. Inconsistency in definitions of diarrhea, severity, resolution of symptoms, recurrence, or cure contributed to the difficulty in drawing conclusions from the evidence.1

Table 1 Key questions and summary of results from CER

Key Question | Summary Results
1) How do different methods for detection of toxigenic Clostridium difficile to assist with diagnosis of CDI compare in their sensitivity and specificity? | - Immunoassays for toxins A and B: Ten studies directly compared at least 2 immunoassays for toxins A and B, providing 16 pairwise comparisons of 7 different immunoassays. Comparative data were not found for many currently used tests. There were no statistical differences between the sensitivities of immunoassays that were compared; however, the estimates of the differences in sensitivity were not very precise and could not rule out substantial differences. Substantial differences in false positives, that is, specificity, were not found among the tests that were compared.; - Gene detection tests versus immunoassays for toxins A and B: Four studies compared at least one toxin gene detection test to at least one immunoassay for toxins A and B, providing a total of nine direct comparisons. Comparative data were not always available for the three currently available gene detection tests. The gene detection tests could be substantially more sensitive than many immunoassays for toxins A and B, with no or relatively modest loss of specificity.; - Patient characteristics: Insufficient patient information was provided in reports of comparative data.
2) What are effective prevention strategies? | - Antibiotic use: Sixteen studies, including six bundled prevention practice studies, found appropriate prescribing practices are associated with decreased CDI incidence. Harms were not reported.; - Gloves: One controlled trial found use of gloves in hospital settings reduced CDI incidence.; - Disposable thermometer: Three time series/before–after studies, two with controls, found use of disposable thermometers in hospital settings reduced CDI incidence.; - Handwashing/alcohol gel: No study examined whether handwashing reduced CDI incidence. Two studies, one controlled trial and one before–after study, of use of alcohol gel to reduce MRSA transmission did not find significant differences in CDI incidence.; - Disinfection: Thirteen before–after studies of outbreaks or endemic hospital settings found intensive disinfection with a chemical compound that kills C. difficile spores reduced CDI incidence.; - Sustainability: No evidence was available.; - Risk Factors: Ten observational studies found evidence that antibiotic use, whether specific or general, increased risk of CDI.; - Severe underlying disease, acid suppression, and age are indicated as risk factors. A number of other potential factors may be indicated in single studies.; - Multiple component strategies: Eleven time series/before–after studies examined bundles of prevention components in a single intervention. Data is insufficient to draw conclusions. Harms were not reported.
3) What are the comparative effectiveness and harms of different antibiotic treatments? | - Vancomycin versus metronidazole: There were 3 head-to-head trials with a total of 335 subjects. Trials used various definitions of CDI patient and cure definitions, especially with regard to stool count and consistency. No significant differences in outcomes, including initial cure, clinical recurrence, and mean days to resolved diarrhea, were found. Our results build upon, and are consistent with, the Cochrane Reviews search completed by Bricker et al.; - Severe disease, vancomycin versus metronidazole: One RCT examined a prespecified subgroup of 69 subjects with severe CDI; Improved clinical cure based on per-protocol analysis, but not with strict intention-to-treat analysis.; - Fidaxomycin versus vancomycin: One large, high quality RCT demonstrated decreased recurrence among those receiving fidaxomicin.; - All other comparisons of standard treatments: There were eight trials examining: vancomycin versus bacitracin (two trials), vancomycin versus fidaxomicin, vancomycin versus nitazoxanide, vancomycin high versus low dose, vancomycin versus placebo, metronidazole versus nitazoxanide, and metronidazole versus metronidazole plus rifampin (one each). No differences.; - Strain of organism: One RCT (fidaxomicin versus vancomycin) demonstrated decreased recurrence among those receiving fidaxomicin when the infecting organism was a non-NAP1 strain.; - Patient characteristics: No comparative data were available.; - Resistance of other pathogens: No data were available.
4) What are the effectiveness and harms of nonstandard adjunctive interventions? | - Treating CDI, active control: Probiotics, prebiotics, C. difficile immune whey, and colestipol are not more effective in treating CDI than standard antibiotic treatment with oral vancomycin or metronidazole or placebo.; - Treating CDI, placebo: Administration of a probiotic with live bacteria to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any known benefit.; - Treating recurrent CDI: There is limited evidence from two case series that fecal flora reconstitution is effective in treating recurrent CDI for up to 1 year.; - Preventing CDI: There is limited evidence that the nonstandard interventions in this review are not more effective than placebo for primary prevention of CDI.; - Preventing recurrent CDI: There is limited evidence from one subgroup analysis that a prebiotic may reduce diarrhea recurrence in patients treated for CDI more so than placebo with standard antibiotics. There is limited moderate-strength evidence from one study that monoclonal antibodies are effective in preventing recurrence of CDI.

### Evidence Gaps

There were a number of important evidence gaps identified in the CER.1 Table 2 summarizes the research recommendations from the CER. The analytical framework that guided the CER is provided in Figure 1. The framework lays out the clinical path for patients with the potential to develop CDI, from diagnostic laboratory tests, through their impact on treatment decisions, to implications for prevention strategies.1 The CER Key Questions are identified within the framework (Figure 1).

Table 2 Future research recommendations from comparative effectiveness review

Key Question | Research Gaps | Types of Studies Needed to Answer Questions | Future Research Recommendation
Key Question 1. How do different methods for detection of toxigenic CD compare in their sensitivity, specificity, and predictive values? | - Few comparisons are available; - Heterogeneity is an obstacle; - Unknown what differences in sensitivity and specificity would alter clinician decisionmaking; - Unknown influence of patient and stool characteristics on test sensitivity and specificity | - Comparison of diagnostic tests using same samples, same labs; - Multicenter studies with well-documented patient samples | - Document stool sample characteristics, patient selection criteria, patient characteristics, and signs and symptoms of suspected CDI
Key Question 2. What are effective prevention strategies? | - Little evidence available with clinically important outcomes | - High-quality comparative studies evaluating effectiveness and harms of single and/or multi-component prevention strategies, including cleaning, isolation, antibiotic restriction; - Discrete simulation models | - Pool data from multiple participating hospital sites; - Establish minimum datasets for observational data points that can inform models
Key Question 3. What are the comparative effectiveness and harms of different antibiotic treatments? | - Limited evidence available on whether vancomycin is more effective for severe CDI. | - High-quality comparative studies with adequate power to detect significance in a priori subgroups | - A uniform and clinically relevant definition of severity; - Subgroup analysis may include age, gender, comorbid conditions; - Explicit reporting of adverse events
Key Question 4. What are the effectiveness and harms of nonstandard adjunctive interventions? | - Probiotics as a treatment adjuvant is not supported. Potential harms to seriously ill patients may outweigh potential benefits for further prevention research; - Probiotics as prevention warrants further study; - Further research of monoclonal antibodies for prevention is warranted; - Further research of fecal transplant is warranted | - High-quality comparative studies with adequate power | - Placebo comparators would contribute indirect evidence to help guide potential combination therapies; - Quality research includes power analysis, intention to treat; - Multicenter trials are likely needed to achieve adequate samples; - Probiotics trials for prevention are well represented in ongoing studies; - Patient characteristics for subgroup analysis
Umbrella issues | | | - Adoption of standard definitions for diarrhea, CDI resolution

CDI = Clostridium difficile infection

Figure 1 Analytic framework from CER for CDI diagnostic testing, prevention, and treatment

Figure 1 lays out the clinical path for patients with the potential to develop CDI, from diagnostic laboratory tests, through their impact on treatment decisions, to finally implications for prevention strategies, and locates the key questions of this review within the context of the framework. Diagnostic testing has two parts, the technical efficiency of the tests and diagnostic accuracy. Technical efficiency is outside the scope of this review; rather, for Key Question 1 we focus on the comparative diagnostic accuracy of commonly used rapid tests, such as immunoassays for C. difficile toxin and toxin gene detection tests, which may reduce the time lapse between the onset of symptoms and laboratory confirmation of CDI and treatment decisions. Repeat testing of selected specimens does not provide good comparative information about test accuracy and therefore is not covered in the focused review of diagnostic test accuracy. When a patient is treated for CDI, whether for an initial case, a relapse, or recurrence, the clinical outcomes of interest establish the patient treatment efficacy. Of particular interest, Key Question 3 will compare effectiveness of established treatments used for CDI, particularly vancomycin and metronidazole. For Key Question 4, the clinical question of interest is what nonstandard treatments are being utilized, and their efficacy, particularly for recurrent CDI. After diagnostic accuracy, treatment, and patient outcome efficacy concerns, prevention is a societal-level efficacy measure, as the benefits of prevention of infectious disease can extend beyond the individual patient. This is the area of focus for Key Question 2. Key Question 4 also contributes to this area to the extent that nonstandard treatments assist a patient in fending off an infection.