# Stakeholder Panel

The following individuals served as members of the Stakeholder Panel described in this report. Their contributions were invaluable. They were given the opportunity to review the report during the public comment period.

Mary Butler, Ph.D.

Minnesota Evidence-based Practice Center

Minneapolis, MN

Erik Dubberke, M.D.

Washington University School of Medicine

St. Louis, MO

Helen Haskell, M.A.

Mothers Against Medical Error

Columbia, SC

Inga Himelright, M.D., M.P.H., M.B.A.

Blue Cross and Blue Shield of Tennessee

Chattanooga, TN

Ciarán Kelly, M.D.

Beth Israel Deaconess Medical Center

Boston, MA

Bruce Lee, M.D., M.B.A.

University of Pittsburgh

Pittsburgh, PA

L. Clifford McDonald, M.D.

Centers for Disease Control and Prevention

Atlanta, GA

Kathleen Mullane, D.O., Pharm.D.

University of Chicago

Chicago, IL

Elaine Petrof, M.D., M.Sc.

Kingston General Hospital & Queens University

Kingston, ON, Canada