# Addendum

## October 26, 2012

The report Future Research Needs for Prevention and Treatment of Clostridium difficile Infection was posed for public comment from May 29, 2012, to June 26, 2012.

In response to the comments received the authors add the following discussion points:

- Standardized definitions in a number of areas will be critical to address in future research of prevention and treatment of CDI. These include clinically relevant definitions of disease, disease severity and disease resolution.
- Absent a consensus on a definition of standard of care, methodological transparency will be essential to defining the intervention and comparator in an era where infection control bundles are ubiquitous. To that end, mathematical modeling may be especially helpful in isolating the relative impact of each bundle element.
- Prevention studies should include the contribution of surveillance, perioperative prophylaxis, hand hygiene, and patient education and engagement, and all studies need to consider relevant functional outcomes, such as mobility and duration of diarrhea in an aging population, along with common patient-centered outcomes such as recurrence.
- Future research priorities should include pediatrics and emerging populations such as pregnant, peripartum, and those with inflammatory bowel disease, and interventions in the ambulatory and critical care settings.