# Executive Summary

## Background

Clostridium difficile infection (CDI) is a serious healthcare-associated infection and a growing health care problem, especially with the emergence of more virulent strains in the early 2000s.1 CDI is now the most common cause of nosocomial infectious diarrhea and is increasing in incidence and, in all likelihood, severity.

A comparative effectiveness review (CER) was prepared by the Minnesota Evidence-based Practice Center (EPC) on Comparative Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection (December 2011).1 The purpose of the CER was to provide an overarching assessment of the evidence for comparing the accuracy of diagnostic tests and the effectiveness of prevention and treatment interventions on initial and recurrent CDI-related patient outcomes in adults. The analytical framework that guided the CER is provided in Figure A. The framework lays out the clinical path for patients with the potential to develop CDI, from diagnostic laboratory tests, through their impact on treatment decisions, to implications for prevention strategies.1 Key Questions (KQs) and CER summary follows (Table A):

Figure A Analytic framework from CER for CDI diagnostic testing, prevention, and treatment

Figure A is a flow diagram illustrating the clinical path for patients with the potential to develop Clostridium difficile-associated disease (CDAD), from diagnostic laboratory tests, through their impact on treatment decisions, to finally implications for prevention strategies. It also locates the key questions of the review within the context of the framework. Diagnostic testing has two parts, the technical efficacy of the tests and diagnostic accuracy. After diagnostic accuracy, and treatment, and patient outcome efficacy, is prevention, a societal level efficacy measure, as the benefits of prevention of infectious disease can extend beyond the individual patient.

Table A Key questions and summary of results from CER

Key Question | Summary Results
1) How do different methods for detection of toxigenic Clostridium difficile to assist with diagnosis of CDI compare in their sensitivity and specificity? | - Immunoassays for toxins A and B: Ten studies directly compared at least 2 immunoassays for toxins A and B, providing 16 pairwise comparisons of 7 different immunoassays. Comparative data were not found for many currently used tests. There were no statistical differences between the sensitivities of immunoassays that were compared; however, the estimates of the differences in sensitivity were not very precise and could not rule out substantial differences. Substantial differences in false positives, that is, specificity, were not found among the tests that were compared.; - Gene detection tests versus immunoassays for toxins A and B: Four studies compared at least one toxin gene detection test to at least one immunoassay for toxins A and B, providing a total of nine direct comparisons. Comparative data were not always available for the three currently available gene detection tests. The gene detection tests could be substantially more sensitive than many immunoassays for toxins A and B, with no or relatively modest loss of specificity.; - Patient characteristics: Insufficient patient information was provided in reports of comparative data.
2) What are effective prevention strategies? | - Antibiotic use: Sixteen studies, including six bundled prevention practice studies, found appropriate prescribing practices are associated with decreased CDI incidence. Harms were not reported.; - Gloves: One controlled trial found use of gloves in hospital settings reduced CDI incidence.; - Disposable thermometer: Three time series/before–after studies, two with controls, found use of disposable thermometers in hospital settings reduced CDI incidence.; - Handwashing/alcohol gel: No study examined whether handwashing reduced CDI incidence. Two studies, one controlled trial and one before–after study, of use of alcohol gel to reduce MRSA transmission did not find significant differences in CDI incidence.; - Disinfection: Thirteen before–after studies of outbreaks or endemic hospital settings found intensive disinfection with a chemical compound that kills C. difficile spores reduced CDI incidence.; - Sustainability: No evidence was available.; - Risk Factors: Ten observational studies found evidence that antibiotic use, whether specific or general, increased risk of CDI.; - Severe underlying disease, acid suppression, and age are indicated as risk factors. A number of other potential factors may be indicated in single studies.; - Multiple component strategies: Eleven time series/before–after studies examined bundles of prevention components in a single intervention. Data is insufficient to draw conclusions. Harms were not reported.
3) What are the comparative effectiveness and harms of different antibiotic treatments? | - Vancomycin versus metronidazole: There were 3 head-to-head trials with a total of 335 subjects. Trials used various definitions of CDI patient and cure definitions, especially with regard to stool count and consistency. No significant differences in outcomes, including initial cure, clinical recurrence, and mean days to resolved diarrhea, were found. Our results build upon, and are consistent with, the Cochrane Reviews search completed by Bricker et al.; - Severe disease, vancomycin versus metronidazole: One RCT examined a prespecified subgroup of 69 subjects with severe CDI; Improved clinical cure based on per-protocol analysis, but not with strict intention-to-treat analysis.; - Fidaxomycin versus vancomycin: One large, high quality RCT demonstrated decreased recurrence among those receiving fidaxomicin.; - All other comparisons of standard treatments: There were eight trials examining: vancomycin versus bacitracin (two trials), vancomycin versus fidaxomicin, vancomycin versus nitazoxanide, vancomycin high versus low dose, vancomycin versus placebo, metronidazole versus nitazoxanide, and metronidazole versus metronidazole plus rifampin (one each). No differences.; - Strain of organism: One RCT (fidaxomicin versus vancomycin) demonstrated decreased recurrence among those receiving fidaxomicin when the infecting organism was a non-NAP1 strain.; - Patient characteristics: No comparative data were available.; - Resistance of other pathogens: No data were available.
4) What are the effectiveness and harms of nonstandard adjunctive interventions? | - Treating CDI, active control: Probiotics, prebiotics, C. difficile immune whey, and colestipol are not more effective in treating CDI than standard antibiotic treatment with oral vancomycin or metronidazole or placebo.; - Treating CDI, placebo: Administration of a probiotic with live bacteria to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any known benefit.; - Treating recurrent CDI: There is limited evidence from two case series that fecal flora reconstitution is effective in treating recurrent CDI for up to 1 year.; - Preventing CDI: There is limited evidence that the nonstandard interventions in this review are not more effective than placebo for primary prevention of CDI.; - Preventing recurrent CDI: There is limited evidence from one subgroup analysis that a prebiotic may reduce diarrhea recurrence in patients treated for CDI more so than placebo with standard antibiotics. There is limited moderate-strength evidence from one study that monoclonal antibodies are effective in preventing recurrence of CDI.

Limited high-quality evidence was available to support the diagnostic, preventive, and treatment practices for CDI carried out by providers in hospital, long-term care, and outpatient settings.1 Inconsistency in definitions of diarrhea, severity, resolution of symptoms, recurrence, or cure contributed to the difficulty in drawing conclusions from the evidence.1 There were a number of important evidence gaps identified in the CER.1 Table B summarizes the research recommendations from the CER. The objective of this Future Research Needs project was to systematically prioritize evidence gaps on prevention and treatment of CDI, and to develop a list of research questions to address the prioritized gaps. Although different diagnostic methods for toxigenic Clostridium difficile were evaluated in the CER, diagnostic methods were not included in this project primarily because polymerase chain reaction testing is rapidly becoming the standard diagnostic test for the infection.

Table B Future research recommendations from CER1

Key Question | Research Gaps | Types of Studies Needed to Answer Questions | Future Research Recommendation
Key Question 1. How do different methods for detection of toxigenic CD compare in their sensitivity, specificity, and predictive values? | - Few comparisons are available; - Heterogeneity is an obstacle; - Unknown what differences in sensitivity and specificity would alter clinician decisionmaking; - Unknown influence of patient and stool characteristics on test sensitivity and specificity | - Comparison of diagnostic tests using same samples, same labs; - Multicenter studies with well-documented patient samples | - Document stool sample characteristics, patient selection criteria, patient characteristics, and signs and symptoms of suspected CDI
Key Question 2. What are effective prevention strategies? | - Little evidence available with clinically important outcomes | - High-quality comparative studies evaluating effectiveness and harms of single and/or multi-component prevention strategies, including cleaning, isolation, antibiotic restriction; - Discrete simulation models | - Pool data from multiple participating hospital sites; - Establish minimum datasets for observational data points that can inform models
Key Question 3. What are the comparative effectiveness and harms of different antibiotic treatments? | - Limited evidence available on whether vancomycin is more effective for severe CDI. | - High-quality comparative studies with adequate power to detect significance in a priori subgroups | - A uniform and clinically relevant definition of severity; - Subgroup analysis may include age, gender, comorbid conditions; - Explicit reporting of adverse events
Key Question 4. What are the effectiveness and harms of nonstandard adjunctive interventions? | - Probiotics as a treatment adjuvant is not supported. Potential harms to seriously ill patients may outweigh potential benefits for further prevention research; - Probiotics as prevention warrants further study; - Further research of monoclonal antibodies for prevention is warranted; - Further research of fecal transplant is warranted | - High-quality comparative studies with adequate power | - Placebo comparators would contribute indirect evidence to help guide potential combination therapies; - Quality research includes power analysis, intention to treat; - Multicenter trials are likely needed to achieve adequate samples; - Probiotics trials for prevention are well represented in ongoing studies; - Patient characteristics for subgroup analysis
Umbrella issues | | | - Adoption of standard definitions for diarrhea, CDI resolution

CDI = Clostridium difficile infection

## Methods

First, evidence gaps were identified through the Minnesota EPC CER. After the CER was published, the literature search was updated and clinicaltrials.gov was searched to identify any ongoing research studies that might address the evidence gaps. Next, stakeholders were identified and through and iterative process the gaps were shared with and refined by these stakeholders. A group of nine stakeholders (Stakeholder Panel), representing diverse perspectives, including methodological/research expertise, clinical experience, and patient and payer representation, was formed; this group prioritized the refined evidence gaps, and generated research questions. Evidence gaps and subsequent research questions for each gap were generated online by the Stakeholder Panel using SurveyMonkey®, an online survey tool. The list of gaps and research questions was then circulated and discussed at the respective Stakeholder Panel teleconference calls. EPC staff compiled a final list, taking the Panel comments into consideration and paying particular attention to areas where ongoing efforts might overlap with prioritized gaps.

In selecting criteria for prioritization, we drew on our experience from a Future Research Needs project for Localized Prostate Cancer, in which the Effective Health Care (EHC) Program Selection Criteria were modified to be applicable to primary research rather than to systematic reviews of original research. The criteria were used to prioritize gaps and research questions. The modified EHC Program Selection Criteria were distributed to panel members each time they were asked to prioritize evidence gaps or research questions. The research questions were characterized using the PICOTS framework using the population (P), intervention (I), comparison (C), outcomes (O), timing (T), and setting (S). The project team then evaluated potential study designs to address each of the research questions. Prioritization of study designs was handled by the EPC in accordance with the recent Future Research Needs methods report by AHRQ.2 The Stakeholder Panel provided insight into how future research agendas and proposed studies to address gaps fit within these prespecified criteria.

## Results

A total of 18 evidence gaps were identified through a combination of the CER findings and conversations with the Stakeholder Panel. These gaps were grouped based on the three key questions addressed in the CER (i.e., prevention, antibiotic treatments, and nonstandard adjunctive interventions). Through an iterative process, the Stakeholder Panel identified and prioritized evidence gaps. The EPC generated the final ranking of four evidence gaps taking all Stakeholder Panel comments into account. The final four research gaps are stated below:

1. Effectiveness and harms of single and/or multi-component prevention strategies for CDI
2. Effectiveness and harms of different strategies for recurrent CDI treatment and prevention
3. Effectiveness and harms of antibiotic treatments for first episode of CDI
4. Effectiveness and harms of fecal transplantation for management of CDI

These four evidence gaps were considered a priority in need of further research primarily given that the information at present is insufficient or imprecise that precludes conclusions from being made about each gap. The Panel then generated and prioritized a list of potential research questions to address these gaps. The final prioritized list of research gaps and research questions accompanied by PICOTS elements are stated in Table C. For the assessment of study designs, EPC staff evaluated the appropriateness of various designs (i.e., randomized controlled trial, nonrandomized comparative trial, prospective cohort, retrospective cohort, nested case-control, case-control, before-after study, modeling) for each prioritized research question.

Table C Prioritized list of evidence gaps and research questions

Evidence Gap | Research Question | Population | Intervention | Comparator | Outcomes | Timing | Setting
Effectiveness and harms of single and/or multi-component prevention strategies for CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Not the right information (results not applicable to setting of interest). | [underlined: 1.1] What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings? [underlined: 1.2] What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings? | Hospital inpatients, ambulatory care patients, residents of any healthcare facility without symptoms/ diagnosis of CDI on admission | Novel strategy (+ standard care)e.g., intensified environmental cleaning | Standard care alone | Primary: change in acquisition incidence of CDI, adverse events; secondary: changes in antibiotic usage, antimicrobial resistance, length of stay, barriers to implementation, mortality | Defined a priori | Hospital, ambulatory care, nursing home
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.1] What is the comparative effectiveness of different treatment options for recurrent CDI? | Patients with laboratory confirmed recurrence of CDI of any disease severity | Novel therapye.g., monoclonal antibody, drug ACT-179811 | different treatment options (standard care) | Primary: initial response to therapy (e.g., mean days to resolution of diarrhea, clearance of toxin, persistence of the organism), harms; secondary: recent antibiotic history, sustained response, mortality. | Duration of followup of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence (for prospective studies) | Hospital, outpatient clinics
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.2] What are the factors/determinants that make for better recurrence prevention for CDI? | The PICOTS on this question will depend on study question and design
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention Reason(s) for Gap: Insufficient or imprecise information (limited number of studies). | [underlined: 2.3] To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates? | Patients being treated for CDI or who have completed CDI treatment | Concomitant antibiotic administered either during or after CDI therapy | No concomitant antibiotic or an alternative concomitant antibiotic | Initial response rate and sustained response rate for CDI, harms, time to initial response, duration of CDI therapy, mortality | A few weeks | Any healthcare setting
Effectiveness and harms of antibiotic treatments for first episode of CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Not the right information (optimal/most important outcomes not addressed) | [underlined: 3.1] What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI? | Patients diagnosed with CDI | Novel therapy e.g., modified release metronidazole, fixadomycin with vancomycin | Vancomycin or metronidazole | Primary: Initial response e.g. resolution of diarrhea at end of treatment (~10 days), harms, recent antibiotic history; secondary: sustained response (i.e. initial response without recurrence), mean days to resolution of diarrhea, death | Variable but likely a few weeks | Hospital, nursing home, long-term care facility, community
Effectiveness and harms of fecal transplantation for management of CDI Reason(s) for Gap: Insufficient or imprecise information (limited number of studies); Information at risk of bias (major methodological limitations in studies) | [underlined: 4.1] What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI? | Patients with laboratory confirmed recurrence of CDI of any disease severity | Fecal transplantation | Vancomycin or metronidazole | Primary-initial response to therapy (e.g., mean days to resolution of diarrhea, clearance of toxin, persistence of the organism), harms; secondary: recent antibiotic history, sustained response, mortality. | Duration of followup of 2 weeks should be sufficient for initial response and 6–8 for sustained response without recurrence (for prospective studies) | Hospital, outpatient clinics

## Discussion

This Future Research Needs project was built from the Minnesota EPC CER. We used a multidisciplinary Stakeholder Panel of nine participants using an 11-step process to identify and prioritize evidence gaps and key research questions across the selected gaps. The final research questions, reflecting the breadth of the original key questions on prevention and treatment of CDI, address a variety of interventions and outcomes for the initial disease and of CDI recurrence. Through this process, we propose a final list of four evidence gaps and seven associated research questions.

It should be noted that the Stakeholder Panel highlighted evidence gaps that were outside the CER scope, such as the need for more research into the epidemiology of CDI and basic science to understand the microbiology. Gaps in the existing epidemiologic knowledge base should be identified with corresponding research projects targeted to fill those gaps. We used multiple techniques to engage stakeholders, including individual interviews, online surveys and conference calls. The literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials to which further research would add the greatest value.

One of the major challenges we encountered in our process was to maintain the focus on the key questions (and scope) addressed in the original CER. It was important on being very explicit about the original scope of the CER as well as the scope of this future research needs effort. There also were several ways to combine/categorize many of the proposed topics; there was crossover and overlap between the various evidence gaps, and the key underlying research questions were addressed within the top-ranked four gaps. In addition, during discussions on research questions, outcomes of interest for certain questions were deemed to be difficult to address in future studies.

## Conclusions

The following four prioritized evidence gaps and seven research questions were identified (Table D).

Table D Prioritized evidence gaps and research questions

Evidence Gap | Research Question
Effectiveness and harms of single and/or multi-component prevention strategies for CDI | [underlined: 1.1] What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings? [underlined: 1.2] What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings?
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention | [underlined: 2.1] What is the comparative effectiveness of different treatment options for recurrent CDI? [underlined: 2.2] What are the factors/determinants that make for better recurrence prevention for CDI? [underlined: 2.3] To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates?
Effectiveness and harms of antibiotic treatments for first episode of CDI | [underlined: 3.1] What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI?
Effectiveness and harms of fecal transplantation for management of CDI | [underlined: 4.1] What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI?

## References

1 Butler M, Bliss D, Drekonja D, et al. Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection, Comparative Effectiveness Review No. 31. (Prepared by the Minnesota Evidence-based Practice Center under Contract No. 290-02-0009) AHRQ Publication No. 11(12)-EHC051-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2011.
2 Carey T, Sanders GD, Viswanathan M, Trikalinos TA, Kato E, Chang S. Framework for Considering Study Designs for Future Research Needs, Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012.