# Discussion

Using the 2011 Minnesota EPC evidence report on the Comparative Effectiveness of Early Diagnosis, Prevention, and Treatment of Clostridium difficile Infection1, we developed an 11-step process for identifying and prioritizing clinically important evidence gaps and research questions, with key input from a diverse group of stakeholders. The final research questions, reflecting the breadth of the original Key Questions on prevention and treatment of CDI, address a variety of interventions and outcomes for the initial disease and of CDI recurrence. Through this process, we propose a final list of four evidence gaps and seven associated research questions.

It should be noted that the Stakeholder Panel highlighted evidence gaps that were outside the scope of the original review, such as the need for more research into the epidemiology of CDI and basic science to understand the microbiology. While these are important areas of interest, the state of the evidence on these aspects was not examined in the CER, and research may have been conducted in this area. There was agreement among the Panel members as to the importance of these issues that current limitations in the published literature, while not reviewed here, provide an opportunity for advancement in the field. Research into the epidemiology and the microbiology (e.g., understanding the gut microbiome) of CDI may be broadened. Gaps in the existing epidemiologic knowledge base should be identified with corresponding research projects targeted to fill those gaps.

There are several strengths to our process. First, it is important that Panel members came forth from a wide range of relevant disciplines to ensure a balanced and broad perspective on research needs that addressed the Key Questions from the CER on prevention and treatment of CDI. Each stakeholder was highly interested and committed. There were high levels of participation at each step. One Panel member was part of the Technical Expert Panel for the original CER. In addition, we had the lead investigator of the CER on our Panel; her insight into the report and the future research recommendations provided “first-hand” knowledge of the content of the CER. The consumer perspective was especially useful in drawing attention to ways in which patients experience care and the impact of illness on other aspects of their lives (e.g., work). The consumer representative particularly addressed prioritizing patient-centered outcomes of interest including the need for more awareness and knowledge on the available treatment options for CDI and further efforts towards better patient reporting and education strategies.

Second, given the breadth of potential topics, the introductory one-on-one calls with panelists helped establish the preliminary list of evidence gaps. This made the first conference call with the stakeholder panel more productive. Third, the literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials to which further research would add the greatest value. Given the large scope of the project, it was helpful to the project team to organize the literature search update and stakeholder information according to broader themes that evolved into specific categories (prevention, treatment). These themes allowed the team to cover more comprehensively aspects of prevention and disease management along the continuum of care, care settings, and populations. The project team also sought feedback from the stakeholders to identify key published studies and ongoing trials across the short-list of evidence gaps.

Finally, the Internet surveys were very successful in prioritizing issues across a broad range of categories. When provided with information on available research, rankings by the Stakeholder Panel appeared to be based on the amenability to CER. A number of stakeholders were complimentary of our process. The Panel members agreed that the final list of evidence gaps and research questions covered key topics for future study in the area of prevention and treatment of CDI. All Panel members, for example, agreed that it is important to address gaps in the existing knowledge base of current infection control practices for CDI in health care institutions.

We encountered several challenges to our process. First, one of the major challenges was to maintain the focus on the key questions (and scope) addressed in the original CER. It was important on being very explicit about the original scope of the CER as well as the scope of this FRN effort. The evidence gaps were grouped by categories that could be linked back to the CER scope, as the team had the evidence reviews and the updated literature search to back the findings. Second, there were several ways to combine/categorize many of the proposed topics. There was crossover and overlap between the various evidence gaps, and the key underlying research questions were addressed within the top-ranked four gaps. The categorization was dependent on how the Stakeholder Panel wanted to approach different topic areas. For example, the proposed topics could be categorized as prevention of Clostridium difficile colonization or infection, treatment of the initial disease, and then treatment of recurrence. Furthermore, the questions in the latter category could be further divided into those addressing prevention/treatment of first recurrence, or of multiple recurrences. Other options discussed earlier in the process were to group the research questions into short or intermediate goals (e.g., understanding the gut microbiome is a long-term type of endeavor which has the potential to lead to new therapeutics, but in the interim, they are critical needs for immediate therapeutic options and prevention).

Finally, during discussions on research questions, outcomes of interest for certain questions were deemed to be difficult to address in future studies. For example, despite its importance, it would be difficult to study the comparative effectiveness of specific infection control measures to control and prevent CDI in non-outbreak settings (question #1) given the multiple (and varied) interventions adopted by institutions. It is essential in this context to ensure that the appropriate controls are set in place in order to assess the impact of these interventions. Much effort will be required to tease out the incremental impact of bundled components, which include predominantly multiple infection control measures and antibiotic stewardship. The utility of decision modeling (as an alternate study design) was discussed to address strategies for prevention of CDI as a way to determine the efficacy of current and future prevention programs.