# Conclusions

This Future Research Needs project was built from the Minnesota EPC CER. We used a multidisciplinary stakeholder panel of nine participants using an 11-step process to identify and prioritize evidence gaps and key research questions across the selected gaps. The results of this process are the four prioritized evidence gaps and seven research questions in Table 12.

Table 12 Prioritized evidence gaps and research questions

Evidence Gap | Research Question
Effectiveness and harms of single and/or multi-component prevention strategies for CDI | [underlined: 1.1] What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings? [underlined: 1.2] What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings?
Effectiveness and harms of different strategies for recurrent CDI treatment and prevention | [underlined: 2.1] What is the comparative effectiveness of different treatment options for recurrent CDI? [underlined: 2.2] What are the factors/determinants that make for better recurrence prevention for CDI? [underlined: 2.3] To what extent do concomitant antibiotics administered during or after CDI therapy contribute to lower/delayed initial response rates and sustained response rates?
Effectiveness and harms of antibiotic treatments for first episode of CDI | [underlined: 3.1] What is the comparative effectiveness of new antibiotic interventions compared with standard therapy (metronidazole, vancomycin) for management of CDI?
Effectiveness and harms of fecal transplantation for management of CDI | [underlined: 4.1] What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI?