# Survey Results of Research Questions with List of Ongoing Studies

Rank | Research Questions | Total Votes | Weighted Score | Ongoing Trials (ClinicalTrials.Gov)
1 | What is the comparative effectiveness of infection control measures to control and prevent CDI in non-outbreak settings? | 7 | 27 | 1. Hospital Design and Risk of Nosocomial Infections: A Prospective Controlled Trial. NCT00563186. 2009; Recruiting (Hospital-Acquired Infection With Clostridium Difficile/Hospital-Acquired VRE Infection or Colonization/Hospital-Acquired MRSA Infection or Colonization). Epub March 6, 2009. http://ClinicalTrials.gov/show/NCT00563186; 2. A Randomized Trial Comparing Matt and Antimicrobial Cellomed Laminates. NCT01245829. 2011; Not yet recruiting (Cross Infection/Infection Control). Epub November 22, 2010. http://ClinicalTrials.gov/show/NCT01245829
2 | What is the comparative effectiveness of fecal transplantation as an adjunctive or alternative therapy versus antibiotics for management of recurrent CDI? | 6 | 17 | 1. Oral Vancomycin Followed by Fecal Transplant Versus Tapering Oral Vancomycin. NCT01226992. 2013; Recruiting (Recurrent Clostridium Difficile Infection/Lab or Pathology Confirmed Clostridium Difficile). Last Updated: October 22, 2010. http://ClinicalTrials.gov/show/NCT01226992; 2. A Randomized Trial of Fecal Transplantation Versus Oral Vancomycin for Recurrent Clostridium Difficile Infection. NCT01398969. 2013; Not yet recruiting (Clostridium Difficile Infection). Last Updated: July 20, 2011. http://ClinicalTrials.gov/show/NCT01398969
3 | What is the comparative effectiveness of different treatment options for recurrent CDI? | 5 | 17 | 1. Optimal Surgical Treatment Of Fulminant Clostridium Difficile Colitis. NCT01441271. 2013; Not yet recruiting (Clostridium Difficile Colitis). Last Updated: September 23, 2011. http://ClinicalTrials.gov/show/NCT01441271; 2. Intracolonic Vancomycin Therapy in Severe C. Diff Colitis. NCT01346059. 2012; Recruiting (Colitis). Last Updated: April 29, 2011. http://ClinicalTrials.gov/show/NCT01346059; 3. A Safety, Tolerability and Pharmacokinetic Study of Two Formulations of Metronidazole Versus Immediate Release Metronidazole in Patient With C. Difficile Colitis. NCT01559545. 2012; Not yet recruiting (Clostridium Difficile Associated Diarrhea). Last Updated: March 20, 2012. http://ClinicalTrials.gov/show/NCT01559545; 4. ACT-179811 in Patients With Clostridium Difficile Infection. NCT01222702. 2012; Recruiting (Clostridium Difficile Infection). Last Updated: January 11, 2012. http://ClinicalTrials.gov/show/NCT01222702; 5. A Study of MK-6072 and MK-3415A in Participants Receiving Antibiotic Therapy for Clostridium Difficile Infection (MK-3415A-002). NCT01513239. 2014; Recruiting (Clostridium Difficile Infection). Last Updated: February 29, 2012. http://ClinicalTrials.gov/show/NCT01513239; 6. A Study of MK-3415, MK-6072, and MK-3415A in Participants Receiving Antibiotic Therapy for Clostridium Difficile Infection (MK-3415A-001 AM2). NCT01241552. 2014; Recruiting (Clostridium Difficile Infection). Last Updated: February 29, 2012. http://ClinicalTrials.gov/show/NCT01241552
3 | What are the factors/determinants that make for better recurrence prevention for CDI? | 5 | 17 | 1. Fidaxomicin to Prevent Clostridium Difficile Colonization. NCT01552668. 2013; Not yet recruiting (Clostridium Difficile Infection). Last Updated: March 12, 2012. http://ClinicalTrials.gov/show/NCT01552668; 2. Study of a Clostridium Difficile Toxoid Vaccine (ACAM-CDIFF™) in Subjects With Clostridium Difficile Infection. NCT00772343. 2011; Active, not recruiting (Diarrhea/Clostridium Difficile Infection). Last Updated: October 5, 2011. http://ClinicalTrials.gov/show/NCT00772343; 3. A Study of MK-6072 and MK-3415A in Participants Receiving Antibiotic Therapy for Clostridium Difficile Infection (MK-3415A-002). NCT01513239. 2014; Recruiting (Clostridium Difficile Infection). Last Updated: February 29, 2012. http://ClinicalTrials.gov/show/NCT01513239; 4. A Study of MK-3415, MK-6072, and MK-3415A in Participants Receiving Antibiotic Therapy for Clostridium Difficile Infection (MK-3415A-001 AM2). NCT01241552. 2014; Recruiting (Clostridium Difficile Infection). Last Updated: February 29, 2012. http://ClinicalTrials.gov/show/NCT01241552; 5. Safety and Efficacy Study of VP20621 for Prevention of Recurrent Clostridium Difficile Infection. NCT01259726. 2012; Recruiting (Clostridium Difficile Infection). Last Updated: October 5, 2011. http://ClinicalTrials.gov/show/NCT01259726; 6. Role of Probiotics in Preventing Antibiotic Associated Diarrhoea Including c.Difficile. NCT01087892. 2011; Recruiting (Antibiotic Associated Diarrhoea Including c.Difficile). Last Updated: July 20, 2010. http://ClinicalTrials.gov/show/NCT01087892
5 | What is the comparative effectiveness of new antibiotic interventions compared to standard therapy (metronidazole, vancomycin) for management of CDI? | 5 | 15 | 1. A Safety, Tolerability and Pharmacokinetic Study of Two Formulations of Metronidazole Versus Immediate Release Metronidazole in Patient With C. Difficile Colitis. NCT01559545. 2012; Not yet recruiting (Clostridium Difficile Associated Diarrhea). Last Updated: March 20, 2012. http://ClinicalTrials.gov/show/NCT01559545; 2. ACT-179811 in Patients With Clostridium Difficile Infection. NCT01222702. 2012; Recruiting (Clostridium Difficile Infection). Last Updated: January 11, 2012. http://ClinicalTrials.gov/show/NCT01222702; 3. Safety and Efficacy of Multiple Daily Dosing of Oral LFF571 in Patients With Moderate Clostridium Difficile Infections. NCT01232595. 2011; Recruiting (Moderate Clostridium Difficile Infection). Last Updated: April 5, 2011. http://ClinicalTrials.gov/show/NCT01232595
6 | What is the incremental impact of various strategies to reduce antibiotic usage, such as antibiotic stewardship programs, on clinical outcomes in non-outbreak settings? | 5 | 13 | None identified
7 | What is the optimal duration of treatment of CDI with concomitant antibiotic usage? | 3 | 9 | None identified
8 | What is the comparative effectiveness of vancomycin vs. other antibiotic regimens for severe CDI? | 3 | 8 | None identified
9 | What is the safest and most effective strategy to perform fecal transplantation (i.e., enema, endoscopic delivery via upper or lower gastrointestinal tract, enteric coated capsules, delivery via nasogastric tube) to obtain the desired effects/benefits? | 3 | 6 | None identified
10 | What is the impact of regular antibiotics use on rates for C. difficile re-infection? | 2 | 4 | None identified
11 | What is the appropriate protocol for donor screening in fecal transplantation for safety? | 1 | 2 | None identified