# Survey Results of Evidence Gaps with List of Preliminary Research Questions

Rank | Evidence Gap | Total Votes | Weighted Total | Preliminary research questions/issues
1 | Effectiveness of single and/or multi-component prevention strategies (e.g., cleaning, isolation, antibiotic stewardship) on reducing CDI rates in non-outbreak settings | 6 | 22 | - What is the effectiveness of hand-washing (with or without alcohol-based gel or other prophylaxis) as a measure to control and prevent CDI?; - What is the incremental impact of various prevention strategies (especially antibiotic stewardship) and the different transmission interruption measures?; - From a payer perspective what are the most effective strategies that can decrease morbidity (and decrease costs)?
2 | Role of increased knowledge of GI microflora and the microbiome towards impact of disease prevention and management strategies for CDI | 6 | 21 | - What is the metagenomic signature of the intestinal microbiotia that predisposes to C. difficile?; - Role of colonization resistance in holding C. difficile in check and understanding through the metagenomics how this is working and the mechanisms through which this works
3 | Mapping of CDI (from antibiotic exposures to disruption of microbiota to risk for C. difficile) | 4 | 17 | - To be defined
4 | Epidemiology of CDI (e.g., sources of C. difficile in the community, exposure to antibiotics in different settings, typing of different strains) | 5 | 14 | - Longitudinal studies of the epidemiology of the population outside the hospital setting; - How the exposure to antibiotics in one setting affects the risk in another setting; - Typing of different strains
5 | Effectiveness of different treatment options for high-risk patients and relapse/recurrent patients | 4 | 12 | - Which treatment choices impact a second episode (relapse or recurrence) with C. difficile?
6 | Effectiveness of new antibiotic interventions for prevention and management of CDI? | 3 | 11 | - What is the impact of regular antibiotics use on rates for C. difficile re-infection?
7 | Effectiveness of fecal transplantation for management of CDI | 4 | 8 | - How invasive do fecal transplantation procedures need to be to obtain the desired effects/benefits?; - What is the appropriate protocol for donor screening in fecal transplantation for CDI (e.g., preparation, procedure)?; - Can the fecal transplantation procedure be standardized by consensus until we have more randomized, controlled trials?
8 | Effectiveness of vaccines for the primary prevention of CDI | 3 | 8 | - What is the effectiveness of vaccines for the primary prevention of CDI in special populations (i.e., nursing homes)?
9 | Effectiveness of antibiotic treatments for severe CDI | 2 | 6 | - To be defined
10 | Role of different patient characteristics (e.g., immunodeficiency) that impact CDI? | 1 | 5 | - What factors are associated with poor outcomes (e.g., concomitant antibiotics) for CDI?
11 | Effectiveness of novel interventions for management of CDI (e.g., toxin binders, immunotherapies) | 1 | 3 | - What is the efficacy of toxin binders as a secondary prophylaxis?; - There is a need for more literature on the subject of immune response (e.g., protective epitopes) which could prevent colonization or disease; - What is the role of adjuvant interventions in patients with severe, progressive, or advanced disease
12 | Effectiveness of probiotics for prevention and management of CDI | 1 | 2 | - What is the effectiveness of probiotics vs. fecal transplant as treatments for recurrent CDI?; - Which selective probiotics can be used to prevent re-infection?; - Can combination probiotics be used to create a polymicrobial environment similar to fecal transplantation?
13 | Modes of transmission of C. difficile in the health care setting (e.g., food, asymptomatic carriers, beddings/linens) | 2 | 2 | - What is the contribution of asymptomatic carriers to C. difficile transmission in long-term care patients (which asymptomatic patients are at most risk for transmission)?; - Among asymptomatic carriers what environmental hygiene measures can reduce transmission rates?; - Need to better understand the transmission dynamics of C. diff. which in turn will inform the effectiveness of prevention strategies and treatment strategies
14 | Duration of treatment with concomitant antibiotics | 1 | 2 | - How long patients need to be treated if they require concomitant antibiotics
15 | Factors/determinants that make for better recurrence prevention for CDI | 1 | 1 | - To be defined
16 | Effectiveness of monoclonal antibodies for the primary prevention of CDI | 1 | 1 | - To be defined
17 | Effectiveness of different patient education strategies to increase awareness of CDI | 0 | 0 | - How can reporting of CDI be improved with regard to accuracy and availability to the public?; - Since more CDI are occurring in the community then before, how can patient education be improved to increase awareness of the disease?
18 | Role of non-antibiotic interventions (e.g., PPIs) and physiological factors (e.g., intestinal microbiota) towards increased incidence of CDI | 0 | 0 | - To be defined (20% of people with C. diff are getting it without previous antibiotics)

Note: The evidence gaps considered outside the original scope of the CER are shaded.