# Search Strategy for Ongoing Studies

MEDLINE®/PubMed
1. (clostridium difficile infection) OR difficile [tiab] OR c-difficile[tiab] OR clostridium difficile [mesh]
2. clostridium[title] OR (c diff*) OR (c difficile) OR difficile
3. (randomized controlled trial*) OR (comparative study) OR (controlled clinical trial) OR RCT[title] OR randomized[tiab] OR placebo[tiab] OR trial[tiab]
4. (1 OR 2) AND 3

January 2012 to Present

Cochrane Library
1. (clostridium difficile infection) OR difficile [tiab] OR c-difficile[tiab] OR clostridium difficile [mesh]
2. clostridium[title] OR (c diff*) OR (c difficile) OR difficile
3. 3. (randomized controlled trial*) OR (comparative study) OR (controlled clinical trial) OR RCT[title] OR randomized [title] OR placebo[title, abstr] OR trial[title]
4. (1 OR 2) AND 3

Limit to: CCTR

January 2012 to Present

ClinicalTrials.Gov
1 (clostridium difficile infection) OR difficile OR c-difficile OR clostridium difficile OR clostridium OR c-diff*
4 1 AND 2

Ongoing Trials