# Summary of Evidence from Comparative Effectiveness Review

Appendix Table A1 Key Question 1 – Diagnostics

Key Questions | Level of Evidence | Summary/Conclusion/Comments
Immunoassays for toxins A and B | Low to moderate | Ten studies directly compared at least 2 immunoassays for toxins A and B, providing 16 pairwise comparisons of 7 different immunoassays. Comparative data were not found for many currently used tests. There were no statistical differences between the sensitivities of immunoassays that were compared; however, the estimates of the differences in sensitivity were not very precise and could not rule out substantial differences. Substantial differences in false positives, that is, specificity, were not found among the tests that were compared.
Gene detection tests versus immunoassays for toxins A and B | Low to moderate | Four studies compared at least one toxin gene detection test to at least one immunoassay for toxins A and B, providing a total of nine direct comparisons. Comparative data were not always available for the three currently available gene detection tests. The gene detection tests could be substantially more sensitive than many immunoassays for toxins A and B, with no or relatively modest loss of specificity.
Patient characteristics | Insufficient | Insufficient patient information was provided in reports of comparative data.

Appendix Table A2 Key Question 2 – Prevention

Key Questions | Level of Evidence | Summary/Conclusion/Comments
Antibiotic use | Low | Sixteen studies, including six bundled prevention practice studies, found appropriate prescribing practices are associated with decreased CDI incidence. Harms were not reported.
Gloves | Low | One controlled trial found use of gloves in hospital settings reduced CDI incidence.
Disposable thermometer | Low | Three time series/before–after studies, two with controls, found use of disposable thermometers in hospital settings reduced CDI incidence.
Handwashing/alcohol gel | Low | No study examined whether handwashing reduced CDI incidence. Two studies, one controlled trial and one before–after study, of use of alcohol gel to reduce MRSA transmission did not find significant differences in CDI incidence
Disinfection | Low | Thirteen before–after studies of outbreaks or endemic hospital settings found intensive disinfection with a chemical compound that kills C. difficile spores reduced CDI incidence.
Sustainability | Insufficient | No evidence was available.
Risk factors | Low | Ten observational studies found evidence that antibiotic use, whether specific or general, increased risk of CDI. Severe underlying disease, acid suppression, and age are indicated as risk factors. A number of other potential factors may be indicated in single studies.
Multiple component strategies | Insufficient | Eleven time series/before–after studies examined bundles of prevention components in a single intervention. Data is insufficient to draw conclusions. Harms were not reported.

Appendix Table A3 Key Question 3 - Antibiotic Treatment

Key Questions | Level of Evidence | Summary/Conclusion/Comments
Vancomycin versus metronidazole | Moderate for clinical cure, low for all other outcomes | There were 3 head-to-head trials with a total of 335 subjects. Trials used various definitions of CDI patient and cure definitions, especially with regard to stool count and consistency. No significant differences in outcomes, including initial cure, clinical recurrence, and mean days to resolved diarrhea, were found. Our results build upon, and are consistent with, the Cochrane Reviews search completed by Bricker et al.^109^
Severe disease, vancomycin versus metronidazole | Insufficient | One RCT examined a prespecified subgroup of 69 subjects with severe CDI; Improved clinical cure based on per-protocol analysis, but not with strict intention-to-treat analysis
Fidaxomycin versus vancomycin | Moderate | One large, high quality RCT demonstrated decreased recurrence among those receiving fidaxomicin.
All other comparisons of standard treatments | Moderate for vancomycin vs. fidaxomicin, low for all other comparisons | There were eight trials examining: vancomycin versus bacitracin (two trials), vancomycin versus fidaxomicin, vancomycin versus nitazoxanide, vancomycin high versus low dose, vancomycin versus placebo, metronidazole versus nitazoxanide, and metronidazole versus metronidazole plus rifampin (one each). No differences.
Strain of organism | Low | One RCT (fidaxomicin versus vancomycin) demonstrated decreased recurrence among those receiving fidaxomicin when the infecting organism was a non-NAP1 strain.
Patient characteristics | Insufficient | No comparative data were available.
Resistance of other pathogens | Insufficient | No data were available.

Appendix Table A4 Key Question 4 - Nonstandard Treatment

Key Questions | Level of Evidence | Summary/Conclusion/Comments
Treating CDI, active control | Low | Probiotics, prebiotics, C. difficile immune whey, and colestipol are not more effective in treating CDI than standard antibiotic treatment with oral vancomycin or metronidazole or placebo.
Treating CDI, placebo | Low | Administration of a probiotic with live bacteria to treat CDI in critically ill patients increases risk for greater morbidity and mortality from fungemia without any known benefit.
Treating recurrent CDI | Low | There is limited evidence from two case series that fecal flora reconstitution is effective in treating recurrent CDI for up to 1 year.
Preventing CDI | Low | There is limited evidence that the nonstandard interventions in this review are not more effective than placebo for primary prevention of CDI.
Preventing recurrent CDI | Low to moderate | There is limited evidence from one subgroup analysis that a prebiotic may reduce diarrhea recurrence in patients treated for CDI more so than placebo with standard antibiotics. There is limited moderate-strength evidence from one study that monoclonal antibodies are effective in preventing recurrence of CDI.

CDI = Clostridium difficile infection; RCT = randomized controlled trial