# Acknowledgments

The research team would like to acknowledge the following individuals for their contributions to this report: Claudia Bonnell, B.S.N., M.L.S., and Elaine Alligood, M.L.S., for literature searching and retrieval; Elizabeth Adams, M.P.H., for assistance with study design considerations; Ryan Chopra, M.P.H., for assistance with the online survey instrument; Kathleen M. Ziegler, Pharm.D., for editorial input and assistance; Lisa Sarsany, M.A., for Federal Government project management; Sharon Flaherty, M.A., for Federal Government contracts support; Lisa Garofalo, B.A. for administrative support; and David Samson, M.S., for his useful and comprehensive advice.