# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CD: Clostridium difficile
CDI: Clostridium difficile infection
CER: Comparative effectiveness review
EHC: Effective Health Care
EPC: Evidence-based Practice Center
FRN: Future research needs
KI: Key informants
KQs: Key Questions
LU: Literature update
NAP1: North American pulsed-field gel electrophoresis type 1
PCR: Polymerase chain reaction
RCT: Randomized controlled trial