# Results

## Research Needs

The FRN identification process led to the nomination of 16 topics (Table 3). The five topics with the highest number of stakeholder endorsements constitute the highest priority FRN topics. The first four are based directly on evidence gaps identified in the CER. These topics pertain to interrelated issues such as the lack of longer term studies to evaluate persistence of BP control or clinical benefit from SMBP, uncertainty regarding what populations are likely to benefit from SMBP, lack of standardization in the prescription of SMBP, and uncertainty regarding the most effective additional support. The fifth prioritized topic, the cost-effectiveness of SMBP, was not included in the CER; it pulls together the issues raised in the top four topics, and, thus, is hindered by the lack of adequate evidence regarding the other research topics.

Table 3 Prioritized and other nominated topics for future research needs in SMBP research

Topic^*^ | Topic Questions | # of Stakeholder Endorsements
| Prioritized future research needs topics
1 | What are the effects of SMBP on BP, medication adherence rates, satisfaction, and clinical outcomes after followup periods of 2 to 5 years or longer? | 7
2 | Which patients may be more likely to benefit from using SMBP? | 6
3 | What is the best prescription or protocol for SMBP (when, how often, and how frequently)? How do different prescriptions for SMBP compare regarding acceptance by patients, adherence with SMBP, and effect on BP control? | 8
4 | What is the role of additional support? What particular components of additional support should be further evaluated? | 7
5^†^ | What is the effect of SMBP on resource utilization? What is the cost-effectiveness of SMBP? | 7
| Other nominated future research needs topics
6^†^ | What are the best tools to educate providers regarding use of SMBP? | 3
7^†^ | What are the best tools to educate patients regarding use of SMBP? | 3
8^†^ | How should SMBP measurements be aggregated or synthesized? For example as BP means, confidence intervals, range including measures of variability (e.g., episodic highs, standard deviations)? Or as pulse pressure? How do different metrics of aggregated SMBP readings predict risk for cardiovascular disease? | 3
9^†^ | How can SMBP be integrated into the patient centered medical home or into multifaceted approaches to improve cardiovascular disease risk management? | 3
10^†^ | How do readings from clinic BP and SMBP compare with each other in their ability to predict CVD risk, and for setting treatment targets? | 2
11^†^ | What is the effect of different device features to minimize errors on quality and accuracy of reading and to enhance adherence? | 2
12^†^ | Should SMBP measurements be recorded blindly (i.e., automatically) or not? What is the impact on accuracy and anxiety and BP control? | 1
13 | What are the best approaches for transmitting the readings? | 1
14 | What are the potential harms of SMBP? Which patients may be more likely to experience harms? | 1
15^†^ | How and how often should the accuracy of a SMBP device in a particular patient be checked in the office to ensure its accuracy for the individual patient? | 0
16 | How does including nocturnal SMBP reading compare with no nocturnal SMBP readings in use of SMBP? | 0

Abbreviations: BP=blood pressure; CVD=cardiovascular disease; SMBP=self-measured blood pressure monitoring

* Prioritized topics (1–5) are ordered logically by clinical content. Other nominated topics are listed in the order they were prioritized by the stakeholder panel.

† Topic was not covered by the SMBP CER. For Topic 12, only the second question was not addressed by the SMBP CER.

SMBP requires patient participation to assess and improve BP control. Since hypertension is a long-term condition and BP changes with age, acute illness, and comorbidities, achieving optimal control requires long-term monitoring. The benefits of long-term BP control are presumed to include a reduction in clinical cardiovascular outcomes; therefore, the need to demonstrate that SMBP has long-term benefit is paramount to establishing a justification for SMBP. Thus, the first topic (Topic 1) is focused on the need for longer term studies and plays a central role also for the remaining topics. At the same time, since long-term effects of SMBP may be modulated by patient and disease factors, SMBP prescription, and types of additional support, considerations for Topics 2, 3, and 4 affect research design deliberations for Topic 1.

### High-Priority Future Research Needs Topic 1 What Are the Effects of SMBP on BP, Medication Adherence Rates, Satisfaction, and Clinical Outcomes After Followup Periods of 2 to 5 Years or Longer?

#### Background

The SMBP CER identified three related evidence gaps pertinent to long-term followup. The followup periods in the comparative studies included in the CER were limited, with most studies not extending beyond 12 months; the comparative studies generally lacked clinical outcomes, with only 1 of 47 studies reporting clinical outcomes; and there were no data linking BP outcomes and clinical outcomes. Therefore, it is currently uncertain if patient adherence to SMBP is sustained beyond 1 to 2 years, whether the effect of SMBP on BP reduction is durable beyond 1 to 2 years, or whether this effect translates into improved clinical or patient reported outcomes. The stakeholders noted that wide coverage of SMBP devices by payers is unlikely unless there is evidence for longer term efficacy and utility (see Topic 5).

#### Proposed Study Designs

##### Randomized Controlled Trial

###### Value of Study Design

Randomized controlled trials (RCTs) provide the most rigorous study design for examining comparative effectiveness for clinical outcomes. RCTs comparing SMBP alone versus usual care, SMBP with additional support versus usual care, or SMBP with additional support versus SMBP alone would produce the most rigorous comparative data. A reasonable time frame for such studies would be 2 to 3 years to demonstrate prolonged effects. Trials should be pragmatic, with wide eligibility criteria and diverse settings to enhance the relevance of their findings. The most direct evidence corroborating a link between surrogate outcomes of BP control with a composite clinical cardiovascular outcome would be derived from RCTs reporting both surrogate outcomes and clinical endpoints; this would require large groups with 5 to 10 years of followup (See Figure 2 for power calculation).

Figure 2 Sample size for a randomized controlled trial for a composite CVD outcome

Total sample size for an RCT with a 1:1 ratio between 2 arms, 80 percent power, two-sided type I error rate (alpha) of 5 percent, and no loss to followup.

Figure 2 is a 3-dimentional bar chart to display the sample sizes for a randomized controlled trial of self measured blood pressure monitoring (SMBP) versus usual care at 3 hypothetical risk ratios (0.8, 0.85, 0.9) and at 4 control rates (0.03, 0.05, 0.1, and 0.15). At a control rate of 0.15, the sample size needed for detecting a risk ratio of 0.8 is 4,068, for 0.85, it is 7,404, and for 0.9, it is 17,044. At a control rate of 0.1, the sample size needed for detecting a risk ratio of 0.8 is 6,418, for 0.85, it is 11,702, and for 0.9 it is 26,982. At a control rate of 0.05, the sample size needed for detecting a risk ratio of 0.8 is 13,466, for 0.85, it is 24,596, and for 0.9, it is 56,794. At a control rate of 0.03, the sample size needed for detecting a risk ratio of 0.8 is 22,866, for 0.85, it is 41,786, and for 0.9, it is 96,544.

RCTs would also allow for the examination of the modifying effects of patient and disease characteristics (see Topic 2), of different prescription and administration regimes of SMBP (see Topic 3), and of additional support combined with SMBP (see Topic 4). Longer term RCTs examining resource use are further expected to yield data for modeling the cost-effectiveness and utility of SMBP (see Topic 5).

Alternatively, a comparative trial of SMBP can be embedded into a larger trial of cardiovascular disease (CVD) risk reduction; for example, studies of treatments for hypertension, diabetes, or cardiovascular disease. One such study is the National Heart, Lung, and Blood Institute's Ischemia Trial3 This study compares medical therapy with more invasive approaches for treatment of patients with stable ischemic heart disease. The study aims to enroll approximately 8000 patients. Followup is approximately 4 years, with the primary study outcome being a composite outcome of cardiovascular death or nonfatal myocardial infarction. SMBP can be compared against usual care by nesting within the medical therapy arm or by using a 2x2 factorial design.

A large body of evidence derived from hypertension trials links BP reduction with antihypertensive treatment to reduced CVD morbidity and mortality. The effect of BP reduction and improvement of CVD may be qualitatively similar between studies of antihypertensive agents and studies of SMBP, since the mechanism through which SMBP would lower CVD (i.e., antihypertensive treatment) is the same. Still, indirect comparisons across different interventions lower our confidence in the strength of evidence. For example, SMBP may lower CVD risk through effects beyond better BP control, such as through lifestyle modification.

Assuming evidence from large hypertension trials can be extrapolated to studies of SMBP, longer term RCTs of SMBP could focus on demonstrating an effect on long-term adherence to SMBP, adherence with antihypertensive medication, achieving BP control and patient satisfaction, to alleviate the concern about loss of efficacy over time. This would require smaller sample sizes than for trials with CVD outcomes as the effect sizes would be larger.

An additional approach to decrease the necessary sample size would be to exclude individuals with a pronounced “white coat effect”, that is, individuals with clinic BP readings that are disproportionately higher than their home averages. In these individuals, if BP is managed based on home BP reading, this will result in higher clinic BPs. Combining individuals with and without a white coat effect in a study and basing BP treatment on home readings could result in opposing actions in medication management and dilution or cancellation of the overall effect on clinic BP.

###### Resource Use, Size, and Duration

An RCT, especially one with a long duration and large sample size, is a highly resource-intensive endeavor. The decision to conduct such a trial must be balanced against the value of the information that can be gained from longer followup and wider representation.

To estimate an appropriate trial sample size, we carried out a power calculation using standard formulas for a two-sided equivalence test. Given the lack of data for the effects of SMBP on a composite cardiovascular outcome, we used data from an existing hypertension trial.4 This trial, the Heart Outcomes Prevention Evaluation (HOPE) study, compared treatment with the antihypertensive ramipril to placebo in individuals at increased cardiovascular risk, based on the presence of the combination of either vascular disease or diabetes and at least one additional cardiovascular risk factor. In the study, ramipril treatment was reported to reduce SBP by 3 mmHg and DBP by 2 mmHg, with a relative risk of 0.78 for a composite cardiovascular outcome of myocardial infarction, stroke, or death from cardiovascular causes. The event rate in the entire control group over a mean of 5 years was 18 percent. In the smaller subgroup of individuals with diabetes mellitus and one additional cardiovascular risk factor (i.e., those without a history of cardiovascular disease) it was lower at 10 percent. For our calculations, we modeled control rates of 15 percent or less, since individuals with hypertension who do not have clinical cardiovascular disease or diabetes would be expected to have lower risk of cardiovascular disease. Furthermore, trials of lower risk individuals would be more applicable to the general population of patients with hypertension than trials restricted to high-cardiovascular risk patients.

For the estimate of the effect size we reviewed the BP effect in the SMBP CER. Although the BP effect was stronger for the combination of SMBP with additional support, we considered the more modest BP reduction for SMBP alone (approximately 2 mm Hg SBP), which is less than the 3 mmHg change for ramipril in the HOPE study. Also, ramipril may improve CVD outcomes through pathways independent of BP reduction, especially in those with CVD or DM. Therefore we also used lower effect sizes than those achieved in HOPE.

We did not consider loss-to-followup in our estimates. However, loss-to-followup in the trials reviewed for the SMBP CER was as high as 20 percent at 12 months. This would require further increases in sample size to compensate for dropouts as well as decreasing adherence with SMBP and crossover of study participants from one group to another.

Our calculated total sample sizes for relative risk (in a two-arm RCT with a 1:1 ratio between arms, two-sided type I error rate [alpha] of 5 percent, and 80 percent power) for each combination of estimated relative risk and control rate are presented in Figure 2.

Depending on the specific control rate and relative risk, the total number of subjects required would range from 4,000 to 97,000 subjects per study. Thus, the feasibility of a trial of cardiovascular end-points in individuals with hypertension without other CVD risk factors is limited.

For trials examining the outcome of BP control, that is, achievement of a BP below a specific BP target, the duration of followup can be shorter and the sample size smaller, such as was the case for a recent 24-month SMBP trial.5 To detect a 10 percent improvement in BP control rates at 24 months with 80 percent power, a type I error rate of 5 percent, the study calculated 570 patients were needed (across 4 arms). However to account for an estimated 24-month dropout rate of 15 percent, the study enrolled 636 individuals divided into 4 arms (159 per arm) and it was in fact adequately powered to show a significant difference of 11 percent. For studies of categorical BP outcomes (i.e., achievement of BP target), sample size needs may vary depending on the discrepancy between the baseline BP and the BP target.

###### Ability To Recruit

There should be no major barriers to recruitment for RCTs addressing this evidence gap. The intervention (SMBP) is low-risk, pain-free, unlikely to be a substantial burden for people interested in controlling their BP, and encourages people to be more involved in their health care.

###### Ethical Issues

There is sufficient equipoise to continue conducting trials of SMBP. It is unlikely that patients would be unduly coerced to participate in such a trial. Confidentiality is presumed.

##### Observational Studies

###### Value of Study Design

Observational studies can compare outcomes for SMBP users versus nonusers. However, observational studies are subject to biases due to the lack of randomization. Established methodological approaches such as matching and regression analysis, including propensity score analyses, may be used to reduce biases from known imbalances at baseline. In addition, sensitivity analyses may be used to explore the robustness of findings for nonrandomized comparisons. However, SMBP depends on patient participation, which is subject to complex and poorly measurable or hidden factors, making it unlikely that confounding by selection bias could be adequately overcome. Thus, findings gleaned from cohort studies should be considered as hypothesis-generating rather than confirmatory.

On the other hand, observational studies have the benefit of wider generalizability when data collection occurs in real-life clinical settings and without restrictive inclusion criteria. As an example, in the Veterans Administration (VA) hospital system, SMBP is provided freely to individuals with hypertension. The VA medical system also contains electronic medical and administrative data systems, which reduces the burden for new data collection.

###### Ability To Recruit

There should be no barriers to recruitment for observational studies addressing SMBP.

###### Resource Use, Size, and Duration

The reliance on observational data substantially reduces resource use and increases feasibility in addressing this evidence gap. Post hoc analyses of existing observational studies can be done quickly and with modest resources. Generally, given the ease of retrospective data analysis, care should be taken to avoid biases from exploratory data-mining. Use of existing databases may be incomplete for some variables.

Prospective observational studies allow for purposeful planning to answer hypotheses and more complete collection of relevant data, which can increase validity compared to post hoc observational using existing data. However, prospective planning and data collection consume a greater amount of resources.

###### Ethical Issues

There should be no ethical barriers to the analysis of existing databases or to conducting prospective trials in the investigation of this evidence gap.

### High-Priority Future Research Needs Topic 2 Which Patients May Be More Likely To Benefit From Using SMBP?

#### Background

In the studies eligible for the SMBP CER, subgroup analyses in RCTs studies were few and of low quality. Further, subgroups were defined according to various different characteristics. Overall, subgroup analyses did not exhibit clear signals as to what populations might differentially benefit from SMBP. One study included in the CER addressed how adherence with SMBP monitoring varied by patient factors. Stakeholders agreed that future research to determine which patients would be most likely to benefit from SMBP was important, as it would allow to target SMBP appropriately to those who are likely to benefit.

A number of factors could influence whether a patient derives benefit from SMBP. These include patient demographics, disease characteristics, and CVD risk factors. In addition, the patient's attitude and predisposition toward participation in disease management may impact adherence with SMBP, adherence with medication, BP control, and overall effectiveness. The large number of possible effect modifiers poses a challenge when exploring the heterogeneity of treatment effects.6

#### Proposed Study Designs

##### Randomized Controlled Trial

###### Value of Study Design

The ideal study design for rigorous exploration of treatment effects in a particular group is an RCT. To definitively examine treatment effects for subgroups would require even larger sample sizes than for overall group effects. For example, to determine that both women and men benefit from SMBP, a trial would have to be powered for both groups. To enhance the rigor of subgroup analyses, subgroups must be pre-specified and may require enrollment stratified by the characteristic to ensure adequate sample size per subgroup. Examining the effects of SMBP in the context of a larger RCT of cardiovascular disease risk reduction is an alternative, less resource-intensive option that would also allow for the exploration of subgroup effects, provided that the relevant sample sizes were sufficient.

###### Resource Use, Size, and Duration

An RCT to examine subgroups is a resource intensive endeavor. Examining SMBP in a larger CVD risk reduction trial could reduce this resource requirement.

###### Ability To Recruit

Exploration of subgroups in an RCT may require stratified enrollment. The ability to recruit may depend on how wide a representation is sought for specific characteristics. For example, if a wide range is desired for race, socioeconomic status, and/or specific comorbidities, recruitment would have to recruit populations often underrepresented in clinical trials.

###### Ethical Issues

There should be no ethical issues in conducting subgroup analyses.

##### Observational Studies

###### Value of Study Design

Cohort studies with large sample sizes and diverse populations are suitable to analysis. As a first step, they may serve to compare characteristics of individuals who use or adhere to SMBP. As a second step, candidate predictor variables including sex, age, race/ethnicity, socioeconomic status, disease characteristics, and CVD risk factors, as well as attitudes towards participation in disease management, may be examined as predictors for surrogate and clinical outcomes. Such a cohort could easily allow for multivariable regression analyses that could test multiple potential subgroup characteristics. However, any such analysis would be subject to spurious associations (false positive results) and should be considered to be hypothesis-generating only.

###### Resource Use, Size, and Duration

Use of existing observational data substantially reduces resource use and increases feasibility. Conducting prospective observational studies requires more resources.

###### Ability To Recruit

Exploration of subgroup effects across a wide range of characteristics requires an effort to identify and include a heterogeneous population.

###### Ethical Issues

There should be no ethical barriers to the analysis of existing databases or to conducting prospective trials in the investigation of this evidence gap.

##### Predictive Modeling of Existing Individual Patient Data From RCTs or Observational Cohort Studies

###### Value of Study Design

Applying the results of clinical trials to individual patients can be problematic due to the wide variety of possible patient characteristics, and the misapplication of results to specific subgroups.6 Therefore, when an effect modifier can be captured in a continuous score (as in the Framingham risk score for cardiovascular disease), sample size requirements can be lowered and different thresholds explored. Along with scores for disease severity or risk, predictive scores that capture likelihood of adherence with SMBP or likelihood to achieve BP control. If such scores can be validated to differentiate those likely to use SMBP or achieve BP control and interact with outcomes, they may be used in re-analyses of individual patient trial data to explore the heterogeneity of treatment effects. Development and validation of predictive models in future RCTs would allow exploration of treatment heterogeneity, thus obviating the problem of multiple comparisons for subgroup analyses.

###### Resource Use, Size, and Duration

Resource use for the analysis of existing data is relatively low. Additional data collection may be needed to develop measures that capture self-reported attitudes towards SMBP, or adherence with SMBP, along with the necessary predictors to explore in modeling.

###### Ability To Recruit

Exploration of a predictor for adherence requires inclusion of individuals with clinical diversity including those with lower affinity or ability to participate in a research study.

###### Ethical Issues

There should be no ethical issues involved in reanalyzing existing study data.

### High-Priority Future Research Needs Topic 3 What Is the Best Prescription or Protocol for SMBP? How Do Different Prescriptions for SMBP Compare Regarding Acceptance by Patients, Adherence With SMBP, and Effect on BP Control?

#### Background

The CER on SMBP indicated a wide variability in protocols and prescriptions for SMBP across trials. This highlights a fundamental uncertainty regarding how frequently and at what times BP should be measured, and how reading should be aggregated within or across measurement episodes. A recent consensus statement recommends a prescription for how to implement SMBP measurements. To provide adequate data for making clinical decisions, it recommends taking 2 to 3 BP readings per measurement episode, and measuring twice daily, in the morning and at night, over a period of 1 week to obtain a total of at least 12 readings per week.7 Current guideline recommendations also specify that BP should be measured in a standardized environment, with the patient resting in the seated position, but do not mention how to time measurements in relation to with food intake, exercise, coffee, alcohol.8,9 However, there is no specific guidance on how to adjust measurement frequency based on how well or for how long BP has been controlled.

The stakeholder panel agreed that patients needed evidence-based guidance on how and when to take measurements. There are a large number of possible variations, and variability in the circadian rhythms or lifestyles of patients further requires customization. In narrowing down options of different measurement approaches, convenience and acceptability to patients, as well as value of information derived from the measurements, must be taken into account.

#### Proposed Study Designs

##### Randomized Controlled Trial

###### Value of Study Design

The ideal study would compare different prescriptions and approaches to aggregating readings and examine their effect on adherence to SMBP and BP control. Measuring adherence to SMBP requires standardization for the SMBP frequency prescribed. However, an RCT could compare only a small number of specific SMBP prescriptions or protocols, potentially limiting the applicability of any trial. To be of value, the different SMBP protocols would have to be easily replicable by providers and patients, and preferably should be protocols that are already in common use.

###### Resource Use, Size, and Duration

Resource use depends on the number of comparisons. Any trial would have the same issues regarding required large sample sizes discussed for Topic 1.

###### Ability To Recruit

There should be no barriers to recruitment for RCTs addressing this evidence gap.

###### Ethical Issues

There should be no ethical barriers in using RCTs to investigate this evidence gap.

##### Observational Studies

###### Value of Study Design

The issues regarding the value of observational studies to address this topic would be very similar to those discussed for Topic 1. Observational studies can be used to explore the effect of using different prescriptions and approaches to aggregating readings. Accurate ascertainment of measurement exposure may be challenging. It may have to be evaluated in real time, for example via electronic transmission or storage, rather than retrospectively due to recall bias.

###### Resource Use, Size, and Duration

Resource use would be less than in conducting an RCT.

###### Ability To Recruit

There should be no barriers to recruitment for observational studies addressing this evidence gap.

###### Ethical Issues

There should be no ethical barriers in using observational studies to investigate this evidence gap.

### High-Priority Future Research Needs Topic 4 What Is the Role of Additional Support? What Particular Components of Additional Support Should Be Further Evaluated?

#### Background

The SMBP CER included studies examining SMBP in combination with many forms of additional support. These additional support modalities include education, counseling by a clinician, telemedicine with automatic reminders, electronic data transmission, and integration with medication management. In looking across studies that compared SMBP alone against usual care, and studies that compared SMBP with additional support against usual care, the findings of the CER appeared to indicate that additional support may be synergistic with SMBP in lowering BP. However, it was unclear which specific component of additional support is most synergistic with SMBP. Recent systematic reviews of trials using telemedicine along with SMBP showed greater BP effects when compared with those reported for SMBP with a mix of additional support in the SMBP CER.10,11

Due to the variety in modalities, comparative studies examining every unique combination of SMBP and additional support are not feasible. We specifically asked our stakeholder panel to identify promising types of additional support for future study. The stakeholder panel expressed interest in researching how SMBP may be integrated with electronic health care systems. In addition, the panel was interested in exploring the effectiveness of different means of data transmission as well as feedback to the patient by devices or providers. Furthermore, there was discussion about the merits of telemedicine versus low resource modalities that can be used by patients with a low level of technical literacy.

#### Proposed Study Designs

##### Expert Panel

###### Value of Study Design

We suggest that prior to conducting new research studies on additional support, an expert panel be convened to determine what specific additional support features appear most promising to explore in future research. In addition to representatives from all stakeholder categories, this panel should specifically include pharmacists, experts in telemedicine and bioinformatics, and authorities in adherence and chronic disease management. The main drawback to this approach would be that stakeholder opinion, rather than evidence per se would dictate the choice of additional support modalities. However, given the resources that would be required to investigate all possible additional support modalities, this tradeoff is likely to be reasonable.

###### Resource Use, Size, and Duration

Using an expert panel to identify promising combinations of additional support for future study would be more efficient than large trials comparing many different types of additional support, which would consume a large amount of resources.

###### Ability To Recruit

There should be little difficulty recruiting relevant stakeholders.

###### Ethical Issues

There should be no ethical issues in using an expert panel to investigate this evidence gap.

### High-Priority Future Research Needs Topic 5 What Is the Effect of SMBP on Resource Utilization? What Is the Cost-Effectiveness of SMBP?

#### Background

The SMBP CER did not include cost as an outcome of interest, nor did it address cost-effectiveness. It included resource utilization as an outcome of interest, but the evidence was of low strength. Several stakeholders expressed interest in quantifying how the potential benefits of SMBP (such as improved health outcomes, higher medication adherence, and fewer office visits) weigh against the costs. The use of SMBP requires both an upfront outlay to purchase the device, as well as further costs to the patient and provider in terms of time and resource utilization.

Part of the stakeholder discussion centered on variation in the cost-effectiveness equation for different patients. For example, SMBP monitoring may improve medication adherence for a given patient and lead to fewer office visits to discuss medication issues, but for a different patient, may increase the number of office visits if SMBP leads to more frequent medication adjustments or side effects.

The ability to address Topic 5 hinges on answering Topic 1, as longer term data on medical effectiveness and resource utilization are necessary to estimate the value of SMBP from the societal, payer, and patient perspectives. Similarly, data for Topics 2, 3, and 4 are needed to address the potential value for specific patient subgroups (Topic 2), the comparative value of different SMBP prescriptions or protocols (Topic 3), and the comparative value of additional support (Topic 4).

#### Systematic Review

Evidence regarding the cost and cost-effectiveness of SMBP use was beyond the scope of the SMBP CER, and requires exploration in a separate systematic review in order to ascertain the level of existing evidence. This would entail a search of single arm or parallel arm trials using SMBP that have collected information on resource usage, as well as existing cost-effectiveness analyses (CEAs) on SMBP.

#### Cost-Effectiveness Analysis

We recommend a quality-adjusted cost-benefit analysis comparing the incremental cost-effectiveness of SMBP to that of medical management in patients with hypertension. The proposed CEAs could be designed to assess the value of SMBP over longer term outcomes, as in Topic 1. The proposed analyses should be designed to address issues relevant to other high priority topic areas, such as patient subgroups (Topic 2), comparisons of the expected value of SMBP following alternative prescription strategies (Topic 3), or comparisons of the effects of SMBP with and without additional support (Topic 4).

Preference should be given to a discrete events analysis. Cost estimates should include: the cost of the device, costs of work absenteeism and presenteeism, additional clinical costs from tracking and responding to SMBP monitoring by providers, costs of antihypertensive treatments (possibly including such costs as gym memberships), and costs of clinical outcomes (e.g., hospitalization due to myocardial infarction, carotid stent placement, and premature death). Effect estimates should include: reductions in mortality and morbidity from improved BP control (including both less under- and less overtreatment), adverse events related to antihypertensive use, and changes in quality-of-life and other patient-relevant outcomes.

The proper outcome measure for such analyses is the quality-adjusted life year (QALY) gained per unit of cost, or the gain in expected life-years with adjustments for morbidity, patient-relevant outcomes, and quality of life. Future QALYs and costs should be discounted over the followup period. For any CEA of SMBP, benefit, utility, and cost estimates are best derived from clinical trial data if available, and from observational data if not. These estimates should include clinical, work-related, and quality-of-life outcomes. Probabilistic sensitivity analyses should be conducted on estimated outcome rates, utilities, and cost estimates. A societal perspective should be assumed in the main analysis. Patients' out-of-pocket costs should be included in the main analysis, and the patient perspective should be assumed in a subanalysis. In the absence of clinical data to support a CEA, sensitivity analyses should also include an assessment of how effective SMBP must be in order to be cost-effective, assuming pre-specified cost-effectiveness threshold(s).

##### Value of Study Design

In addition to the expected merit of a simple CEA, sensitivity analyses may be of great value, particularly past the time horizon of 2 years, as clinical data to support a CEA, especially past this time frame, are likely to be very limited.

###### Resource Use, Size, and Duration

Because a CEA can draw from previously collected data, the cost of such a study should be low and the duration to complete such an analysis relatively short. It may, however, be challenging to gather relevant data from payers and providers.

###### Ability To Recruit

Not applicable.

###### Ethical Issues

No new data collection is proposed; therefore, the direct risk to patients is minimal.