# References

1 Concannon TW, Meissner P, Grunbaum JA, et al. A new taxonomy for stakeholder engagement in patient centered outcomes research. JGIM. In press. 2012.
2 Uhlig K, Balk EM, Patel K, et al. Self-Measured Blood Pressure Monitoring: Comparative Effectiveness. Comparative Effectiveness Review No. 45. (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-2007-10055-I). AHRQ Publication No. 12-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2012. [pmid: 22439158].
3 Maron D, Boden W, Ferguson B, et al. ISCHEMIA Trial Protocol Synopsis. 2012. https://ischemiatrial.org/for-physicians/Protocol_Synopsis_Nov.16.11.pdf.
4 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. Jan. 20. 2000;342(3):145-53. [pmid: 10639539].
5 Bosworth HB, Olsen MK, Grubber JM, et al. Two self-management interventions to improve hypertension control: a randomized trial. Ann Intern Med. Nov. 17. 2009;151(10):687-95. [pmid: 19920269].
6 Kent DM, Hayward RA. Limitations of applying summary results of clinical trials to individual patients: the need for risk stratification. JAMA. Sep. 12. 2007;298(10):1209-12. [pmid: 17848656].
7 Pickering TG, Miller NH, Ogedegbe G, et al. Call to action on use and reimbursement for home blood pressure monitoring: executive summary: a joint scientific statement from the American Heart Association, American Society Of Hypertension, and Preventive Cardiovascular Nurses Association. Hypertension. Jul. 2008;52(1):1-9. [pmid: 18497371].
8 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. [Erratum appears in JAMA. 2003 Jul 9;290(2):197]. JAMA. May. 21. 2003;289(19):2560-72. [pmid: 12748199].
9 National Institute for Health and Clinical Excellence. Hypertension: The clinical management of primary hypertension in adults. 2011. http://guidance.nice.org.uk/CG127.
10 Omboni S, Guarda A. Impact of home blood pressure telemonitoring and blood pressure control: a meta-analysis of randomized controlled studies. Am J Hypertens. Sep. 2011;24(9):989-98. [pmid: 21654858].
11 Verberk WJ, Kessels AG, Thien T. Telecare is a valuable tool for hypertension management, a systematic review and meta-analysis. Blood Press Monit. Jun. 2011;16(3):149-55. [pmid: 21527847].