# Methods

## Identification of Evidence Gaps

As the original authors of the SMBP CER, we generated the initial list of FRN topics based on the Research Needs section of the report, and then organized the list of evidence gaps according to Key Questions and PICOD elements. We then used an iterative process to identify additional FRN topics through Webinars and emails with a stakeholder panel. We asked the stakeholder panel to prioritize the FRN topics following a formalized schema of prioritization criteria.

## Criteria for Prioritization

Stakeholders (described in the next section) were asked to consider four dimensions of need. These four dimensions are outlined in the Effective Health Care Program Selection Criteria (Appendix A). Briefly, they are:

- Importance
- Desirability of Research/Avoidance of Unnecessary Duplication
- Feasibility
- Potential Impact

The fifth dimension of the Selection Criteria, appropriateness, was not evaluated by the stakeholders, as AHRQ already deemed the topic of SMBP to adequately meet this criterion. The Effective Health Care Program guidance on these criteria was explained in detail at each Webinar encounter with the stakeholders and was also specified on a worksheet that was distributed for discussion.

To inform the selection criterion of Desirability of Research/ Avoidance of Unnecessary Duplication, we conducted an update of the original CER's MEDLINE^®^ search through January 13, 2012 to find new studies that addressed the CER's Key Questions. The full search is provided in Appendix A (Table A1). We also searched the National Library of Medicine Clinical Trial Registry (www.ClinicalTrials.gov) to identify ongoing or recently completed trials relevant to the CER questions (Appendix A, Table A2). Relevant recently completed or registered studies identified in the searches were compared against the nominated FRN topics to assess if they would make future research on any nominated topic redundant, but none appeared to do so.

## Engagement of Stakeholders, Researchers, and Funders

Although researchers and funders of research are the primary audience for future research needs documents, the EPC solicits input from other stakeholders as well when identifying high priority research gaps and future research needs. Stakeholders are selected to provide broad expertise and a breadth of perspectives, as well as input on the kind of information that is helpful in healthcare decisionmaking. These stakeholders are engaged throughout the future research process. Their role is to (1) review the preliminary list of evidence gaps and possible future research topics derived from them, (2) to nominate additional topics to the list, (3) discuss topic nominations, (4) to participate in prioritization of the future research needs topics. Stakeholders are not involved in translating the gaps into research questions and study designs, composing or reviewing the report. The final future research needs document will be released for public comment. Stakeholders who participated in the future research needs identification process are invited to provide comments on this report during the public posting. Public input may be incorporated into or otherwise reflected in the final report.

We engaged a stakeholder panel representing the stakeholders who use research evidence in health care and public health decisionmaking. To form the panel, we used the Tufts-developed 7Ps model of stakeholder engagement,1 which identifies seven primary stakeholder categories. The stakeholder categories of the 7Ps model consist of:

1. Patients and the public: This group represents current and potential consumers of patient-centered health care and population-focused public health programs. This group also includes caregivers, family members, and patient advocacy organizations, all of whom represent the interests of consumers or patients.
2. Providers: This group includes individuals (e.g., nurses, physicians, and other providers of care and support services) and organizations (e.g., hospitals, clinics, community health centers, pharmacies, emergency medical services agencies, schools) that provide care to patients and populations.
3. Purchasers: This group includes employers; the self-insured; Federal, state, and local governments; and other entities responsible for underwriting the costs of healthcare.
4. Payers: This group represents private insurers, government insurers (e.g., Medicare, Medicaid, the Veterans Administration), and others responsible for reimbursement for care.
5. Policymakers: This group includes entities such as the legislative and executive branches of the Federal and state governments, professional associations, and other intermediary groups that collect and distribute information to policymakers.
6. Principal investigators: This group consists primarily of researchers, and research funders.
7. Product makers: This group consists primarily of manufacturers and device makers.

These categories are not necessarily mutually exclusive, and one stakeholder may belong to more than one category.

We recruited stakeholders representing Patients and the Public, Providers, Payers, Policymakers, and Principal investigators and asked them to provide input foremost according to their designated stakeholder category. We did not specifically recruit stakeholders representing purchasers because their interest in SMBP was not sufficiently different from that of payers. For Product makers, we contacted manufacturers from the list of companies that were sent Scientific Information Packets for the CER. These companies were asked to provide potential FRN topics with rationales, but were not invited to be stakeholders due to the inherent financial conflict of interest.

We identified individuals to serve on the stakeholder panel through several means. We invited some individuals who had previously served in advisory roles on the original SMBP CER. We used our affiliation with the Kidney Disease and Hypertension Outpatient clinic at Tufts Medical Center to identify patients and clinical providers. We used professional contacts to identify public and private payers and a policy maker. Further, our Task Order Officer helped recruit a Medicare representative who represented a payer.

Individuals were selected based on their perceived interest in the topic and their level of previous participation in discussions on the topic, as well as their coverage of a necessary stakeholder category. Our predetermined goal was to assemble a representative panel of 11 stakeholders across the first 6 stakeholder categories (Table 2).

Table 2 List of predetermined target stakeholders

Category | Subcategory | No. of Stakeholders
Patients and the public | Patients with hypertension | 2
Providers | Clinician – MD General Practitioner Clinician – Physician assistant in hypertension clinic Clinician – Nurse Practitioner in hypertension clinic | 3
Payers | Medicaid Medicare Private insurer (Blue Cross Blue Shields) | 3
Policymakers | Health Resources and Services Administration | 1
Principal investigators | Clinical research investigators | 2
Total | | 11

All individuals involved in the project were required to submit a standard disclosure of interest form. Participation was only confirmed after review of the disclosure form. Stakeholders were asked to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because they may be called upon to provide unique clinical or content expertise, stakeholders may potentially be retained even when there are potential conflicts. AHRQ's Task Order Officer and the EPC conferred to approve each stakeholder.

Individuals who met the criteria to participate as a stakeholder were contacted by email with a brief description of the project and its purpose, a formal invitation to serve as a stakeholder, and the executive summary of the original SMBP CER. After confirmation of participation, we sent additional instructions and materials to orient stakeholders as to how the project would proceed. We also sent the Future Research section of the original CER and a proposed outline for the future research needs project.

In January 2012, we conducted a first round of Webinars with stakeholders. In these Webinars, we first explained the purpose and process of FRN topic development. Subsequently stakeholders were asked to self-identify as a representative of a particular stakeholder category and directed to provide feedback chiefly with respect to their primary stakeholder category. We also directed stakeholders to restrict their FRN nominations to topics within the scope of the CER, specifically delineating out-of-scope topics, such as the diagnosis of hypertension or the management of hypertension in pregnant women or in chronic dialysis patients (based on the topic and study eligibility criteria of the SMBP CER). We then reviewed the research gaps identified in the CER and explained the criteria for prioritization. After this orientation, the stakeholders were asked to identify additional FRN topics of interest to them and to discuss their or others' topics, the supporting rationale or related research challenges. Stakeholders were also given the option of nominating additional topics by email.

Topics nominated by stakeholders were incorporated into the topic list along with supporting rationale, which we condensed from the discussion and subsequent emails. We combined duplicate or similar FRN topics together and disseminated the revised list of topics, along with Webinar minutes, with an invitation to comment as to whether the nominated topics and supporting rationales were appropriately recorded and accounted for.

We held a second round of Webinars in February 2012, during which we reviewed the refined list of nominated topics. Stakeholders were asked if their nominations were appropriately captured and accounted for and were able to have additional discussion. We then asked each stakeholder to identify his or her top five priority topics and to provide any justifications based upon the provided criteria for prioritization.

Following this second round, we further edited the topic list based on stakeholder rationale. We also added topic suggestions to the topic list that were made by the product maker representative. We then sent it back to stakeholders. Stakeholders were given one week to provide comments on the revised list by email. Following this commentary period, we finalized the list and asked stakeholders to electronically indicate their top five topic choices using an online application Survey Monkey^TM^ to elicit a structured response. The five topics with the highest number of stakeholder endorsements were designated as the prioritized future research needs topics.

To ensure that input from all stakeholders was heard and considered, great pains were taken to accommodate scheduling restraints for all stakeholders. Composition of each Webinar list of invitees was also carefully planned. In particular, we scheduled a Webinar during the first series for just the two patient representatives to make certain that they had the opportunity to contribute and interact in this way. In total, we were able to almost complete participation of all stakeholders at both Webinars, with one providing input by email in lieu of in-person participation at the second Webinar.

Use of the Effective Health Care Program prioritization criteria was repeatedly emphasized throughout the prioritization process, including during discussion, nomination, and final topic selection. Upon the close of stakeholder prioritization, we identified the top five topics as those most frequently endorsed by stakeholders in their top five selections. The final ranked list was emailed to stakeholders.

## Research Question Development and Research Design Considerations

We transformed the final list of FRN topics into research questions using standard PICOD criteria. (Stakeholders were not utilized during this process.) We discussed various alternatives for future research efforts aimed to answering each question, specifically considering the feasibility of addressing the research questions with respect to potential sample size, the time required, recruitment and ethical issues. In particular, we evaluated the advantages and disadvantages of various potential research designs with regards to:

- Value of study design
- Resource use, size, and duration
- Ability to recruit
- Ethical issues

When randomized trials were deemed to be the most appropriate study design to address a FRN topic, we performed sample size calculations using standard formulae for a two-sided chi-squared test at the 0.05 level of significance. We also examined the literature for estimates of the relative effect between intervention and control. We assumed an allocation ratio of 1:1, no loss to followup, no crossover between treatments, and no sequential monitoring.