# Conclusions

This report identifies five high-priority future research needs to study SMBP, which were identified by a stakeholder panel. These are as follows:

1. What are the effects of SMBP on BP, medication adherence rates, satisfaction, and clinical event outcomes, after longer followup periods 2 to5 years or longer?
2. Which patients may be more likely to benefit from using SMBP?
3. What is the best prescription or protocol for SMBP (when, how often, and how frequently)? How do different prescriptions for SMBP compare regarding acceptance by patients, adherence with SMBP, and effect on BP control?
4. What is the role of additional support? What particular components of additional support should be further evaluated?
5. What is the effect of SMBP on resource utilization? What is the cost-effectiveness of SMBP?

In summary, with regards to addressing these gaps: Longer term randomized controlled trials that examine SMBP effects on BP control and resource utilization are needed; the impact of SMBP on CVD outcomes may be gleaned from embedding SMBP in other CVD outcome trials; the exploration of treatment heterogeneity may identify those groups more likely to benefit from SMPB. When, how often, and how frequently to perform SMBP, and what additional support to employ, should be further refined. Finally, filling these evidence gaps will inform future modeling of cost-effectiveness.