# Background

Hypertension is a common, long-term health condition, particularly prevalent among older adults. Untreated or undertreated hypertension leads to increased cardiovascular morbidity and mortality, as well as increased consumption of health care resources; however, long-term adherence to lifestyle modification and medication remains a challenge. Self-measured blood pressure monitoring (SMBP) has been suggested as one method that may improve adherence to blood pressure (BP) treatment and consequently improve outcomes. SMBP refers to the regular self-measurement of a patient's BP at home or otherwise outside the office or clinic, as a supplement or alternative to those obtained in a health care setting. While patient self-participation in chronic disease management appears to be a promising means of improving adherence, the sustainability and clinical effect of this strategy, as well as its impact on health care utilization, remain uncertain.

The current Future Research Needs (FRN) project was launched upon the completion of an Agency for Healthcare Research and Quality (AHRQ) Comparative Effectiveness Review (CER) on SMBP, and builds on the evidence gaps identified in that review. The present report describes the development of a stakeholder-prioritized list of research needs for that topic, along with a measured consideration of the advantages and disadvantages of various potential research designs, in order to help researchers and funders develop future research proposals or solicitations.

## Scope of CER

The January 2012 CER upon which the current FRN report is based, Self-Measured Blood Pressure Monitoring: Comparative Effectiveness, was sponsored by the Agency for Healthcare Research and Quality and conducted by the Tufts Evidence-based Practice Center (EPC).2 It reviewed pertinent publications through July 2011 and addressed five Key Questions:

1. In people with hypertension (adults and children), does SMBP, compared to usual care or other interventions without SMBP, have an effect on clinically important outcomes?
  a. How does SMBP compare to usual care or other interventions without SMBP in its effect on relevant clinical outcomes (cardiovascular events, mortality, patient satisfaction, quality of life, and adverse events related to antihypertensive agents)?
  b. How does SMBP compare to usual care or other interventions without SMBP in its effect on relevant surrogate outcomes (cardiac measures of left ventricular hypertrophy) and intermediate outcomes (BP control, BP treatment adherence, or health care process measures)?
2. In trials of SMBP, how do clinical, surrogate, and intermediate outcomes (including SMBP adherence) vary by the type of additional support provided?
3. How do different devices for SMBP compare with each other (specifically semiautomatic or automatic versus manual) in their effects on clinical, surrogate, and intermediate outcomes (including SMBP adherence)?
4. In trials of SMBP, how does achieving BP control relate to clinical and surrogate outcomes?
5. How does adherence with SMBP vary by patient factors?

## Findings of the CER

Results and conclusions from the CER are based on 47 comparative studies of at least 8 weeks duration, and one observational study. There were 24 comparisons of SMBP alone versus usual care, 24 of SMBP plus additional support versus usual care, 12 of SMBP plus additional support versus SMBP without additional support or with less intense additional support, and 1 study evaluating predictors of adherence to SMBP. For SMBP alone versus usual care, the strength of evidence was moderate showing a lower BP with SMBP (SBP/DBP [systolic BP/diastolic BP] −3.1/ −2.0 mmHg at 6 months). For SMBP plus additional support versus usual care, the strength of evidence was high showing a lower BP with SMBP use (SBP/DBP −3.4 to −8.9/ −1.9 to −4.4 mmHg) up to 12 months. For SMBP plus additional support versus SMBP alone or with less intense additional support, the strength of evidence was low, and failed to support a difference in BP. For all comparisons, evidence for clinical outcomes was insufficient; for all other non BP outcomes (surrogate and intermediate outcomes, and health care encounters) strength of evidence was low and failed to support a difference. No trials compared different SMBP devices or provided evidence on the relationship between BP control and clinical or surrogate outcomes. There was insufficient evidence concerning predictors of SMBP adherence. None of the studies enrolled children.

## Identification of Evidence Gaps

The 2011 CER on SMBP identified several evidence gaps. Although children were specified as a population of interest, there were no eligible studies conducted in children. Given the rise of hypertension among children, this lack of research represents an important shortcoming in the literature. Refinement of the future research agenda to address this population would require a specially composed stakeholder group with perspectives on the management of hypertension in children. Thus, while the evidence gap in children was noted, it was determined that the current project proceed with a focus on adults only. All other identified evidence gaps are summarized in Table 1, organized and labeled by Key Question and PICOD (Population, Intervention, Comparator, Outcome, study Design) category.

Table 1 Identified evidence gaps organized by relevant Key Question and PICOD element

Key Question | Category | Evidence Gaps (Code^*^)
Key Question 1. In people with hypertension (adults and children), does SMBP, compared to usual care or other interventions without SMBP, have an effect on clinically important outcomes? Key Question 1a. How does SMBP monitoring compare to usual care or other interventions without SMBP in its effect on relevant clinical outcomes (cardiovascular events, mortality, patient satisfaction, quality of life, and adverse events related to antihypertensive agents)? Key Question 1b. How does SMBP compare to usual care or other interventions without SMBP in its effect on relevant surrogate outcomes (cardiac measures: LVH, LVM, LVMI)^*^ and intermediate outcomes BP control, BP treatment adherence, or health care process measures)? | Population | Unclear if treatments or treatment goals differ if a patient has uncontrolled hypertension, white coat hypertension, or masked hypertension (1P1) Unclear if effects from SMBP differ in subgroups, for example older patients, those with comorbidities, and minorities (1P2)
| Intervention/Comparator | Unclear what the BP treatment goals should be for home BP in relation to clinic BP (1I1) Unclear how to compare findings across studies, as different studies use different protocols for SMBP, different additional support and different care in the control groups (1I2) Unclear what the best practice protocol would be for SMBP (1I3) Unclear what the adherence is to SMBP protocols or devices in the long-term (1I4) Unclear how the effect of SMBP can be enhanced by particular additional support (1I5)
| Outcomes | Unclear what the effects are of SMBP on clinical event outcomes, i.e., after longer followup periods (1O1) Unclear if the effect of SMBP is sustained beyond 1-2 years (1O2) Unclear what the effect of SMBP is on patient understanding of disease, and how this correlates with attitudes towards and participation in disease management, medication adherence and BP control (1O3)
| Design | N/A
Key Question 2. In trials of SMBP monitoring, how do clinical, surrogate, and intermediate outcomes (including SMBP adherence) vary by the type of additional support provided? | Population | N/A
Key Question 2. In trials of SMBP monitoring, how do clinical, surrogate, and intermediate outcomes (including SMBP adherence) vary by the type of additional support provided? | Intervention/Comparator | Unclear what the optimal additional support is for facilitating patient-provider interaction, and medication management including telemedicine (2I)
Key Question 2. In trials of SMBP monitoring, how do clinical, surrogate, and intermediate outcomes (including SMBP adherence) vary by the type of additional support provided? | Outcomes | N/A
Key Question 2. In trials of SMBP monitoring, how do clinical, surrogate, and intermediate outcomes (including SMBP adherence) vary by the type of additional support provided? | Design | N/A
Key Question 3. How do different devices for SMBP monitoring compare with each other (specifically semiautomatic or automatic versus manual) in their effects on clinical, surrogate, and intermediate outcomes (including SMBP adherence)? | Population | N/A
| Intervention/Comparator | Unclear if the device type impacts adherence, BP control and outcomes (3I)
| Outcomes | N/A
| Design | N/A
Key Question 4. In trials of SMBP monitoring, how does achieving BP control relate to clinical and surrogate outcomes? | Population | N/A
Key Question 4. In trials of SMBP monitoring, how does achieving BP control relate to clinical and surrogate outcomes? | Intervention/Comparator | N/A
Key Question 4. In trials of SMBP monitoring, how does achieving BP control relate to clinical and surrogate outcomes? | Outcomes | Unclear what the link is between achieving BP control and clinical outcomes (4O)
Key Question 4. In trials of SMBP monitoring, how does achieving BP control relate to clinical and surrogate outcomes? | Design | Need for longer term follow up (4D)
Key Question 5. How does adherence with SMBP vary by patient factors? | Population | N/A
Key Question 5. How does adherence with SMBP vary by patient factors? | Predictor | Unclear how patient characteristics, such as demographic and psychosocial variables, affect adherence to SMBP (5P)
Key Question 5. How does adherence with SMBP vary by patient factors? | Outcomes | Need for validated outcome measures of adherence with SMBP (5O)
Key Question 5. How does adherence with SMBP vary by patient factors? | Design | N/A

Abbreviations: BP=blood pressure; N/A=not applicable; SMBP=self-measured blood pressure monitoring

* The parenthetical alphanumeric code is used to label each evidence gap on the analytic framework (Figure 1). The first number of the alphanumeric code corresponds to the Key Question, the following letter to the PICOD category, and the final numeral to distinguish among multiple gaps within the same Key Question and Domain (if applicable). Where there is only one gap identified, the last number is dropped.

## Analytic Framework

Figure 1 depicts the analytic framework that guided the SMBP CER. It maps the specific linkages associating the populations and subgroups of interest, interventions, and outcomes of interest (intermediate outcomes, health-related outcomes, compliance, and adverse effects) for each Key Question. Specifically, the analytic framework illustrates the chain of logic that the evidence must support to link interventions to improved health outcomes. In addition, we have labeled the figure with each Key Question's identified research gaps.

Figure 1 Analytic framework for SMBP with evidence gaps^*^ * Each gap is indicated with an alphanumeric code, where the first number of the alphanumeric code corresponds to the Key Question, the following letter to the PICOD category, and the final numeral to distinguish among multiple gaps within the same Key Question and category (if applicable). Where there is only one gap identified, the last number is dropped.

Abbreviations: AE=adverse events; BP=blood pressure; CVD=cardiovascular disease; KQ=Key Question; LVH=left ventricular hypertrophy; LVM=left ventricular mass; LVMI=left ventricular mass index; SMBP=self-measured blood pressure.

Figure 1 summarizes the evidence gaps identified in our review of the use of SMBP. The original analytic framework in the comparative effectiveness review was modified to include evidence gaps within the context of PICOD (patient populations, interventions, comparators, outcomes, and study designs of interest). With reference to the coding using in Figure 1, the arrow linking patients with hypertension to clinical outcomes (key question 1a) is associated with evidence gaps 1O1 and 1O2. The arrow linking patients with hypertension to surrogate and intermediate outcomes (key question 1b) is associated with evidence gaps 1O2 and 1O3. Both key questions 1a and 1b are associated with evidence gaps 1P1, 1P2, and 1I1-1I5. The arrow linking additional support to intermediate outcomes is associated with evidence gap 2I, and the arrow linking different SMBP devices to intermediate outcomes is associated with evidence gap 3I. The arrow linking surrogate and intermediate outcomes with clinical outcomes is associated with evidence gaps 4O and 4D. The arrow linking patients with hypertension to intermediate outcomes is associated with evidence gaps 5P and 5O.