# Effective Health Care Program Selection Criteria Literature Search Strategy Yield of Ongoing Studies

## Effective Health Care Program Selection Criteria

Appropriateness
- Represents a health care drug, intervention, device, technology or health care system/setting available (or soon to be available) in the United States.
- Relevant to 1013 enrollees (Medicare, Medicaid, S-CHIP, other federal health care programs.
- Represents one of the priority conditions designated by the U.S. Department of Health and Human Services (HHS).

Importance
- Represents a significant disease burden, large proportion or priority population.
- Is of high public interest; affects health care decision-making, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
- Was nominated/strongly supported by one or more stakeholder groups.
- Represents important uncertainty for decisionmakers.
- Incorporates issues around both clinical benefits and potential clinical harms.
- Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care.
- Represent high costs to consumers, patients, health care systems or payers; due to common use, high unit costs, or high associated costs.

Desirability of New Research/Duplication
- Would not be redundant (i.e., the proposed topic is not already covered by available or soon-to-be available evidence.)

Feasibility
- Effectively uses existing research and knowledge by considering adequacy of research for conducting research, and newly available evidence

Potential Impact
- Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

## Literature Search Strategy

Databases: Ovid MEDLINE, MEDLINE(R) In-Process, Cochrane Database of Systematic Reviews, Cochrane Controlled Trials Register (CCTR)

Search conducted: 1/13/2012

Table A1 Literature search terms organize

# | Searches | Targeting
1 | exp Blood Pressure Monitoring, Ambulatory/ | SMBP
2 | exp Blood Pressure Monitors/ | SMBP
3 | exp Blood Pressure/ | SMBP
4 | exp hypertension/ | SMBP
5 | exp Self Care/ | SMBP
6 | (3 or 4) and 5 | SMBP
7 | ((blood pressure or hypertens$) and self and (measure$ or monitor$ or care or manage$)).mp. | SMBP
8 | 1 or 2 or 6 or 7 | SMBP
9 | randomized controlled trial.pt. | Comparative Studies (KQ 1-3)
10 | controlled clinical trial.pt. | Comparative Studies (KQ 1-3)
11 | randomized controlled trials/ | Comparative Studies (KQ 1-3)
12 | Random Allocation/ | Comparative Studies (KQ 1-3)
13 | Double-blind Method/ | Comparative Studies (KQ 1-3)
14 | Single-Blind Method/ | Comparative Studies (KQ 1-3)
15 | clinical trial.pt. | Comparative Studies (KQ 1-3)
16 | Clinical Trials.mp. or exp Clinical Trials/ | Comparative Studies (KQ 1-3)
17 | (clinic$ adj25 trial$).tw. | Comparative Studies (KQ 1-3)
18 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | Comparative Studies (KQ 1-3)
19 | Placebos/ | Comparative Studies (KQ 1-3)
20 | placebo$.tw. | Comparative Studies (KQ 1-3)
21 | random$.tw. | Comparative Studies (KQ 1-3)
22 | trial$.tw. | Comparative Studies (KQ 1-3)
23 | (randomized control trial or clinical control trial).sd. | Comparative Studies (KQ 1-3)
24 | (latin adj square).tw. | Comparative Studies (KQ 1-3)
25 | Comparative Study.tw. or Comparative Study.pt. | Comparative Studies (KQ 1-3)
26 | exp Evaluation studies/ | Comparative Studies (KQ 1-3)
27 | Follow-Up Studies/ | Comparative Studies (KQ 1-3)
28 | Prospective Studies/ | Comparative Studies (KQ 1-3)
29 | (control$ or prospectiv$ or volunteer$).tw. | Comparative Studies (KQ 1-3)
30 | Cross-Over Studies/ | Comparative Studies (KQ 1-3)
31 | or/9-30 | Comparative Studies (KQ 1-3)
32 | exp cohort studies/ or exp prospective studies/ or exp retrospective studies/ or exp epidemiologic studies/ or exp case-control studies/ | Cohorts (KQ 4)
33 | (cohort or retrospective or prospective or longitudinal or observational or follow-up or followup or registry).af. | Cohorts (KQ 4)
34 | case-control.af. or (case adj10 control).tw. | Cohorts (KQ 4)
35 | ep.fs. | Cohorts (KQ 4)
36 | 32 or 33 or 34 or 35 | Cohorts (KQ 4)
37 | 8 and (31 or 36) | Limits
38 | limit 37 to humans [Limit not valid in CDSR,CCTR; records were retained] | Limits
39 | limit 38 to yr="1888 - 2000" | Limits
40 | remove duplicates from 39 | Limits
41 | limit 37 to yr="2001-2008" | Limits
42 | remove duplicates from 41 | Limits
43 | limit 37 to yr="2009-current" | Limits
44 | remove duplicates from 43 | Limits
45 | or/40, 42, 44
46 | (home adj20 blood pressure).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] | Added Terms
47 | or/9-45 | Added Terms
48 | 46 and 47 | Added Terms
49 | (exp telemedicine/ or exp self-examination/) and (exp Blood pressure/ or exp Hypertension/) | Added Terms
50 | 47 and 49 | Added Terms
51 | 45 or 48 or 50 | Added Terms
52 | (201107$ or 201108$ or 201109$ or 20111$ or 2012$).ed. | Date
53 | 51 and 52 | Final

## Yield of Ongoing Studies

Table A2 Ongoing research on SMBP identified through ClinicalTrials.gov

NCT ID | Title | Recruitment | Interventions | Enrollment
NCT00781365 | Home Blood Pressure Telemonitoring and Case Management to Control Hypertension | Recruiting | Other: Telemonitors and pharmacy management | 450
NCT01145742 | Controlling Hypertension in Diabetes- Feasibility Study | Completed | Behavioral: home health/primary care collaboration | 56
NCT01300338 | Blood Pressure Telemonitoring and Goal Blood Pressure in Diabetes | Not yet recruiting | Device: blood pressure with telemetry | 50
NCT01300338 | Blood Pressure Telemonitoring and Goal Blood Pressure in Diabetes | Not yet recruiting | Device: Home blood pressure monitor without telemetry | 50
NCT01035554 | Behavioral Study to Control Blood Pressure | Recruiting | Other: Self-Paced Programmed Instruction (SPPI) | 250
NCT01035554 | Behavioral Study to Control Blood Pressure | Recruiting | Device: Home Blood Pressure Monitor | 250
NCT01035554 | Behavioral Study to Control Blood Pressure | Recruiting | Other: Usual Care | 250
NCT01035554 | Behavioral Study to Control Blood Pressure | Recruiting | Other: Printed Materials | 250
NCT00662753 | A Study in the Use of Home Blood Pressure Monitoring and Telephone Follow-up to Control Blood Pressure | Recruiting | Device: Home blood pressure monitor | 150
NCT00662753 | A Study in the Use of Home Blood Pressure Monitoring and Telephone Follow-up to Control Blood Pressure | Recruiting | Other: monitor and phone call | 150
NCT00334724 | Home Blood Pressure-guided Antihypertensive Intervention for Elderly (HBP-GUIDE) Study | Completed | Procedure: Home blood pressure measurement | 200
NCT00334724 | Home Blood Pressure-guided Antihypertensive Intervention for Elderly (HBP-GUIDE) Study | Completed | Procedure: Office blood pressure measurement | 200
NCT01123577 | Evaluation of Integrating Self Blood Pressure Monitoring Into Urban Primary Care Practices | Enrolling by invitation | Other: Home Blood Pressure Monitor Group | 996
NCT01123577 | Evaluation of Integrating Self Blood Pressure Monitoring Into Urban Primary Care Practices | Enrolling by invitation | Other: Control Group | 996
NCT00123058 | Comparison of Two Programs to Improve Blood Pressure Treatment Adherence | Active, not recruiting | Behavioral: Health Education Program | 636
NCT00123058 | Comparison of Two Programs to Improve Blood Pressure Treatment Adherence | Active, not recruiting | Device: BP Monitor | 636
NCT00514800 | Home Blood Pressure Monitoring Trial | Recruiting | Behavioral: Intervention - a validated home BP monitor and support from the specialist nurse | 360
NCT00514800 | Home Blood Pressure Monitoring Trial | Recruiting | Behavioral: Control - usual care (BP monitoring by their practice) | 360
NCT00211666 | Improving Hypertension Control in East and Central Harlem | Completed | Behavioral: Nurse management, home blood pressure monitors, and a chronic disease self management course. | 480
NCT00968786 | Home Monitoring in the Management of Hypertension and Diabetes Mellitus | Enrolling by invitation | Device: Home monitoring | 100
NCT00299468 | The Effect of the Patient Activation Measure on Chronic Care | Completed | Behavioral: Patient Activation Measure Intervention Package | 283
NCT01155050 | Louisiana State University Health Care Services Division (LSUHSCD) Tele-Health Projects: Weight Loss in Chronic Disease Patient Population | Completed | Device: Tele-health Home Monitoring | 240
NCT01155050 | Louisiana State University Health Care Services Division (LSUHSCD) Tele-Health Projects: Weight Loss in Chronic Disease Patient Population | Completed | Behavioral: TrestleTree Telephone Coaching | 240
NCT01155050 | Louisiana State University Health Care Services Division (LSUHSCD) Tele-Health Projects: Weight Loss in Chronic Disease Patient Population | Completed | Device: Tele-health Home Monitoring Plus Trestle Telephone Coaching | 240
NCT01282957 | Way to Health, Healthy Measures | Enrolling by invitation | Behavioral: Financial Incentive Group I | 60
NCT01282957 | Way to Health, Healthy Measures | Enrolling by invitation | Behavioral: Financial Incentive Group II | 60
NCT01233193 | The Effect of Pharmacist Intervention on Blood Pressure Control | Active, not recruiting | Behavioral: Health education, Home blood pressure monitoring | 140
NCT00802152 | Using Health Information Technology (HIT) to Improve Ambulatory Chronic Disease Care: Smart Device Substudy | Completed | Device: In-home "smart" diagnostic devices | 108
NCT01167920 | Virtual Hypertension Clinic | Active, not recruiting | Other: Virtual Hypertension Clinic | 74
NCT00233220 | Blood Pressure Control in African Americans | Recruiting | Behavioral: Multicomponent, multi-level intervention targeted at physicians and patients | 990
NCT00233220 | Blood Pressure Control in African Americans | Recruiting | Behavioral: Usual Care | 990
NCT00224861 | Hypertension Telemanagement in African Americans | Completed | Behavioral: Self-Management | nd
NCT00224861 | Hypertension Telemanagement in African Americans | Completed | Behavioral: Adherence | nd
NCT01013857 | Treating to Target for Patients With Hypertension | Active, not recruiting | Behavioral: Health coaching | 240
NCT01013857 | Treating to Target for Patients With Hypertension | Active, not recruiting | Behavioral: Health coaching plus home titration | 240
NCT01335984 | Effects of Telemonitoring and Telemedicine Service for Hypertensive Care (Smart-HTN) | Recruiting | Procedure: Telemonitoring\|Procedure: Telemonitoring & Telemedicine\|Other: Usual Care | 564
NCT01439256 | Telehealth & Remote Measurement Technologies to Improve Medication Adherence in Hypertension | Not yet recruiting | Device: Electronic pill tray direct reporting to physician (Telephone-Linked Care: Hypertension 2- Electronic Pill Tray) Behavioral: Patient self reporting of medication adherence | 258
NCT01504022 | Web Based Interactive Treatment and Self-monitoring in Hypertension (WISH) | Recruiting | Other: Telecare, selfmonitoring, lifestyl behaviour | 300
NCT01416766 | CONtrolling Disease Using Inexpensive IT - Hypertension in Diabetes (CONDUIT-HID) | Recruiting | Other: CONDUIT self-monitoring-nurse-primary care provider (PCP) feedback loop | 400
NCT01510301 | Mobile Phone in Hypertension Management | Not yet recruiting | Device: Mobile phone-based self-report system, electronic Patient-Reported Outcomes Measure (e-PROM) | 50
NCT01387945 | Pilot Study of Home Blood Pressure Control Program (eBPcontrol) | Recruiting | Behavioral: HBPM+website+patient navigator | 30
NCT01402453 | Monetary Incentives and Intrinsic Motivation to Sustain Hypertension Control | Not yet recruiting | Behavioral: Monetary Incentives\|Behavioral: Intrinsic Motivation | 262
NCT01484782 | Developing Accessible Telehealth Programs for Hypertensive Patients in Latin America | Active, not recruiting | Behavioral: Interactive Voice Response (IVR) automated calls | 200
NCT01390272 | Titrated Disease Management for Patients With Hypertension (TDM) | Not yet recruiting | Behavioral: Booster/ low resource Behavioral: Booster/ low resource Behavioral: Medium/Level 1 resource intensity Behavioral: High/Level 2 resource intensity | 400
NCT01425515 | Improving Care for Patients With High Blood Pressure | Not yet recruiting | Behavioral: Complex quality improvement intervention | 600

Abbreviations: BP=blood pressure; CBP=clinic blood pressure; HBP=home blood pressure; HBPM=home blood pressure monitoring; nd=no data.

We used the terms [blood pressure OR hypertension] as a “condition” search string combined with the following search terms for interventions [(home OR ambulatory OR self) AND (monitor* OR telemonitoring OR measure* OR manage*)]