# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BP: Blood pressure
CEA: Cost-effectiveness analysis
CER: Comparative Effectiveness Review
CVD: Cardiovascular disease
DBP: Diastolic blood pressure
EHC: Effective Health Care
FRN: Future Research Needs
HOPE Study: Heart Outcomes Prevention Evaluation Study
PICOD: Population, intervention, comparator, outcome, study design
QALY: Quality-adjusted life year
RCT: Randomized controlled trial
SBP: Systolic blood pressure
SMBP: Self-measured blood pressure monitoring
VA: Veterans Administration