# Results

## Recruitment and Participation

Sixteen of 30 invited stakeholders agreed to participate in the phase 1 semistructured interviews (Figure 3). Overall, we conducted interviews with 6 of the 6 legal/liability or hospital administrators (100 percent); 2 of the 6 patient/consumer advocates (33 percent); 5 of the 13 clinicians (30 percent); 1 of the 2 researchers (50 percent); and 2 of the 3 research funders (66 percent) (Table 1). The category of clinician encompassed nurses, midwives, and physicians. In order to ensure a balance of these clinical perspectives a larger proportion of individuals were recruited from this stakeholder group.

Figure 3 Recruitment and participation

Figure 3 is a flow diagram illustrating recruitment and participation in the study. The figure indicates that 30 individuals and organizations were invited to participate in semi structured interviews and 0 refused, 12 did not respond, and two were unable to reschedule. Sixteen agreed and participated in the Phase 1 interviews. Of those who agreed, 10 (63 percent) were invited to complete Questionnaire 1 online, and one (6 percent) completed the questionnaire by fax. All 11 (100 percent) participants completed Questionnaire 1. Lastly, the final box indicates that all 11 (100 percent) completed Questionnaire 2 the Final Prioritization Ranking.

Table 1 Participants and organizations in phase 1

Stakeholders | Total Invited | Agreed | Participation Rate | Invited Organizations and Individuals
Legal/Liability and Hospital Administrators | 6 | 6 | 100% | The Doctors Company; UCSF/UC Hastings Consortium on Law, Science & Health Policy; OHSU, Risk Management Department
Patient/Consumer Advocates | 6 | 2 | 33% | National Advocates for Pregnant Women; Our Bodies Ourselves; ICAN; What to Expect Foundation
Clinicians | 13 | 5 | 30% | Obstetricians, RNs, Nurse Midwives
Researchers | 2 | 1 | 50% | NICHD; Office of Women's Health Maternal Fetal Medicine, Obstetrics and Gynecology, Northwestern University
Research Funders | 3 | 2 | 66% | Pregnancy and Perinatology Branch, NICHD; Office of Research on Women's Health, NIH
Total | 30 | 16 | 53%

Of the 16 stakeholders interviewed in phase 1, 11 were invited to take part in phase 2 of our study. Phase 2 consisted of two rounds of a Delphi process to identify the highest priority areas for future research. All stakeholders invited to participate in phase 2 completed the first round questionnaire and 10 of the 11 (81 percent) completed the second round questionnaire (Table 2). Of the stakeholders who participated in phase 2, one was a hospital administrator, two were patient/consumer advocates, five were clinicians, one was a researcher, and two were research funders. One of the research funders was unable to take part in the second round due to travel commitments.

Table 2 Participants and organizations in phase 2

Stakeholders | Total Invited | Completed Round 1 | Completed Round 2 | Participation Rate | Participating Organizations and Individuals
Phase II, Delphi
Legal/Liability and Hospital Administrators | 1 | 1 | 1 | 100% (round 1) 100% (round 2) | The Doctors Company; UCSF/UC Hastings Consortium on Law, Science & Health Policy
Patient/Consumer Advocates | 2 | 2 | 2 | 100% (round 1) 100% (round 2) | Our Bodies Ourselves; ICAN
Clinicians | 5 | 5 | 5 | 100% (round 1) 100% (round 2) | Obstetricians, RNs, Nurse Midwives
Researchers | 1 | 1 | 1 | 100% (round 1) 100% (round 2) | Pregnancy and Perinatology Branch, NICHD; Office of Interdisciplinary Research Programs; Office on Women's Health; Maternal Fetal Medicine, Obstetrics and Gynecology, Northwestern University
Research Funders | 2 | 2 | 1 | 100% (round 1) 50% (round 2) | Pregnancy and Perinatology Branch, NICHD; Office of Research on Women's Health, NIH
Total | 11 | 11 | | 100% (round 1) 91% (round 2)

We recognize that stakeholders often wear a number of hats. For the purposes of the phase 2 prioritization, we asked stakeholders to self report their primary perspective. Their self-reported perspectives were then compared with the perspective assigned by the research team to verify accuracy (Table 3). All but one of the self-identified perspectives matched up with that assigned by the research team. The one exception was a stakeholder who we classified as legal/liability and hospital administrator, but whose primary self-identified perspective was clinician. Because the stakeholder self-identified as a clinician and spoke primarily from the clinician perspective, we included the individual's results in the clinician category.

Table 3 Team-assigned and self-identified perspectives of stakeholders: phase 2 Web questionnaire

Respondent | Perspective Assigned | Perspective Chosen
1 | Clinician | Clinician
2 | Research Funder | Research Funder
3 | Consumer Advocate | Consumer Advocate
4 | Researcher | Researcher
5 | Clinician | Clinician
6 | Legal/Liability or Hospital Administration | Lawyer, Law Professor
7 | Consumer Advocate | Consumer Advocate
8 | Legal/Liability or Hospital Administration | Clinician
9 | Clinician | Clinician
10 | Research Funder | Research Funder
11 | Clinician | Clinician

### Phase 1

Data from the series of semistructured stakeholder interviews along with evidence gaps identified in the 2010 evidence review were organized into four overarching thematic categories. The four categories included: (1) health systems; (2) risk, attitudes, and decisionmaking; (3) shared decisionmaking and informed consent; and (4) clinical outcomes for mother and infant. Gaps identified during the 2010 evidence review are integrated into these categories. In analyzing the data from the interviews, we attempted to frame evidence gaps in terms of potential research questions.

The evidence gaps and related research questions identified in phase 1 are listed below.

#### Contextual and health system delivery factors

1. Research on barriers to providing safe trial of labor (TOL), including factors that limit the availability of hospitals to meet the “immediately available” requirement (i.e., availability of anesthesiologists, obstetric providers, and other resources).
2. Studies to test clinical, institutional, or policy interventions to increase access to safe TOL.
3. Studies to understand best practice models based on institutions that are currently offering TOL.
4. Studies to test the effectiveness of simulation training for increasing capacity to offer safe TOL.
5. Clinical and policy relevant studies to address the threat of legal liability on patterns and utilization of TOL (vs. ERCD [elective repeat cesarean delivery]).
6. Studies of the influence of Medicaid policy and private insurance reimbursement on availability of TOL (vs. ERCD).
7. Studies that correlate benefits and harms of VBAC (vaginal birth after cesarean) and ERCD with short- and long-term health system costs.
8. Research on the threshold/tipping point for a change in health policy in response to harms compared with benefits.
9. Studies on the influence of VBAC policies on trends in home births.

#### Risk, attitudes, and decisionmaking

1. Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL compared with ERCD.
2. Research on how providers understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL compared with ERCD.
3. Research on how health system administrators and liability companies understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL compared with ERCD.
4. Studies of the factors shaping patient attitudes and decisionmaking on TOL.
5. Studies of the factors shaping provider attitudes and decisionmaking on TOL.
6. Studies of the factors shaping health system administrator and liability company attitudes and decisionmaking on TOL.
7. Research on the relationship between fear of childbirth and decisionmaking surrounding mode of delivery.

#### Shared decisionmaking and informed consent

1. Studies to understand whether and how patients and providers can work together to make a shared decision about TOL compared with ERCD.
2. Studies comparing the efficacy of different types of decision aids for TOL compared with ERCD.
3. Studies on the timing of administering decision aids or providing other information about the risks and benefits of TOL compared with ERCD (i.e., after a woman's first cesarean birth compared with waiting until her next pregnancy).
4. Studies of how women are consented for both TOL and ERCD and whether consent encompasses risks to current and future pregnancies.
5. Studies to refine, validate, and implement informed consent templates that are informative, reliable and able to be well documented.

#### Maternal and infant outcomes

1. Development of standardized measures for short- and long-term maternal and infant outcomes.
2. Population-level research on patterns of utilization and maternal/infant outcomes of VBAC, TOL with emergent cesarean, and ERCD – stratified by race/ethnicity and socioeconomic status.
3. Development/utilization of a reliable model or tool to predict the probability of successful TOL for individual women.
4. Development of registries to track the frequency and safety of home births, including TOL.
5. Comparative studies of type of provider (obstetrician, midwife, family practice physician) on patterns of utilization and maternal/infant outcomes of TOL compared with ERCD.
6. Comparative studies of delivery setting (tertiary care center, community hospital, free standing birth center, at home) on patterns of utilization and maternal/infant outcomes of TOL compared with ERCD.
7. Investigation of whether antepartum or intrapartum management strategies (such as labor induction) influence rate of TOL compared with ERCD and maternal/infant outcomes.
8. Studies comparing outcomes for mother and infant in settings where physicians are “immediately available” compared with settings where physicians are “readily available.”
9. Comparison of risk of maternal or infant adverse outcomes during childbirth in general compared with risk of adverse outcomes with TOL or ERCD.
10. Studies to compare the affect of TOL compared with ERCD on breastfeeding initiation and continuation.
11. Studies to compare the affect of TOL compared with ERCD on psychosocial outcomes such as maternal-infant bonding and postpartum depression.
12. Surveillance to determine long-term maternal and infant clinical outcomes of TOL compared with ERCD.

### Phase 2

Questions for the first round of the phase 2 prioritization were based on the categories and themes (listed above) that were identified in phase 1. Participants were asked both to (1) rate each evidence gap/research question as high, medium, or low priority and (2) select the 10 highest priority items from the entire list. Respondents were asked to consider criteria such as burden of disease, high public interest, vulnerable populations, utilization of existing resources, and potential impact in making their selections.

After tabulating the number of times that each topic was included as one of the 10 highest priorities and the percentage of respondents who ranked each topic as high, medium, or low priority (Table 4), 15 topics emerged as the top priorities from the first round of the questionnaire. The top 15 priorities are highlighted in bold in Table 4 below. (See Appendix E for the list of topics for prioritization as presented to stakeholders). There was a natural break between the top 15 topics (40–70 percent of respondents included in their top 10) and the remaining 18 topics (30 percent or fewer respondents included in their top 10). We cross referenced the results of the high/medium/low and top 10 rankings to identify any discrepancies. These results were remarkably consistent, with the exception of question 7 (studies that correlate benefits and harms of VBAC and ERCD with short- and long-term health system costs), which was rated high by 63.6 percent of respondents but was only included in one respondent's top 10 research priorities. In other words, although seven respondents ranked question 7 as high priority, when choosing the 10 highest priority questions, only one included question 7.

Table 4 Phase 2, Delphi round 1: detailed responses

Question a | High (%) (n) | Medium (%) (n) | Low (%) (n) | Times Ranked in Top 10
Section IIA: Health System Factors
Q1. Research on barriers to providing safe TOL, including factors that limit the ability of hospitals to meet the “immediately available” requirement (i.e. availability of anesthesiologists, availability of obstetric providers, other resources) | 72.7% (8) | 18.2% (2) | 9.1% (1) | 7
Q2. Studies to test clinical, institutional, or policy interventions to improve safety and availability of TOL | 63.6% (7) | 18.2% (2) | 18.2% (2) | 6
Q3. Studies to understand best practice models based on institutions that are currently offering safe TOL | 72.7 % (8) | 18.2% (2) | 9.1% (1) | 4
Q4. Studies to test the effectiveness of simulation training in increasing capacity to offer safe TOL | 18.2% (2) | 36.4% (4) | 45.5% (5) | 2
Q5. Clinical and policy relevant studies to address the threat of legal liability on practice patterns regarding TOL vs. ERCD | 45.5% (5) | 9.1% (1) | 45.5% (5) | 4
Q6. Studies of the influence of Medicaid policy and private insurance reimbursement on availability of TOL after cesarean vs. ERCD | 18.2% (2) | 36.4% (4) | 45.5% (5) | 2
Q7. Studies that correlate benefits and harms of VBAC and ERCD with short- and long-term health system costs | 63.6% (7) | 36.4% (4) | 0 (0) | 1
Q8. Research on the threshold/tipping point for a change in health policy in response to harms vs. benefits | 27.3% (3) | 54.5% (6) | 18.2% (2) | 0
Q9. Studies on influence of VBAC policies on trends in home births | 9.1% (1) | 36.4% (4) | 54.5% (6) | 0
Section IIB: Risk, Attitudes, and Decisionmaking
Q10. Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | 60.0% (6) | 30.0% (3) | 10.0% (1) | 6
Q11. Research on how providers understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | 63.6% (7) | 36.4% (4) | 0 (0) | 7
Q12. Research on how health system administrators & liability companies understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | 45.5% (5) | 36.4% (4) | 18.2% (2) | 5
Q13. Studies of the factors shaping patient attitudes and decisionmaking on TOL after cesarean | 60.0% (6) | 20.0% (2) | 20.0% (2) | 3
Q14. Studies of the factors shaping provider attitudes and decisionmaking on TOL after cesarean | 60.0% (6) | 30.0% (3) | 10.0% (1) | 6
Q15. Studies of the factors shaping health system administrator & liability company attitudes and decisionmaking on TOL after cesarean | 40.0% (4) | 30.0% (3) | 30.0% (3) | 4
Q16. Research on the relationship between fear of child birth and decisionmaking surrounding mode of delivery | 10.0% (1) | 20.0% (2) | 70.0% (7) | 1
Section IIC: Shared Decisionmaking and Informed Consent
Q17. Studies to understand whether and how patients and providers work together to make a shared decision about TOL vs. ERCD | 40.0% (4) | 30.0% (3) | 30.0% (3) | 2
Q18. Studies comparing the efficacy of different types of decision aids for TOL vs. ERCD | 40.0% (4) | 50.0% (5) | 10.0% (1) | 3
Q19. Studies on the timing of decision aids or other information about the risks and benefits of TOL vs. ERCD (i.e. after the woman's first cesarean vs. waiting until her next pregnancy) | 20.0% (2) | 40.0% (4) | 40.0% (4) | 3
Q20. Studies of how women are consented for both TOL after previous cesarean and ERCD and whether consent encompasses risks to current and future pregnancies | 45.5% (5) | 36.4% (4) | 18.2% (2) | 4
Q21. Studies to refine, validate, and implement informed consent templates that are informative, reliable, and able to be well documented | 36.4% (4) | 45.5% (5) | 18.2% (2) | 4
Section IID: Maternal and Infant Outcomes
Q22. Development of standardized measures for short- and long-term maternal and infant outcomes | 36.4% (4) | 54.5% (5) | 9.1% (1) | 4
Q23. Population-level research on patterns of utilization and maternal/infant outcomes of VBAC, TOL with emergent cesarean, and ERCD, stratified by race/ethnicity and socioeconomic status | 27.3% (3) | 36.4% (4) | 36.4% (4) | 2
Q24. Development/utilization of a reliable model or tool to predict the probability of successful VBAC for individual women | 63.6% (7) | 27.3% (3) | 9.1% (1) | 5
Q25. Development of registries to track frequency and safety of home births, including TOL after cesarean | 18.2% (2) | 36.4% (4) | 45.5% (5) | 1
Q26. Comparative studies of type of provider (OB/GYN, midwife, family practice physician) on patterns of utilization and maternal/infant outcomes of TOL vs. ERCD | 36.4% (4) | 45.5% (5) | 18.2% (2) | 1
Q27. Comparative studies of delivery setting (tertiary care center, community hospital, free standing birth center, at home) on patterns of utilization and outcome of TOL vs. ERCD | 36.4% (4) | 45.5% (5) | 18.2% (2) | 3
Q28. Investigation of whether antepartum or intrapartum management strategies – such as labor induction – influence rate of TOL vs. ERCD and maternal/infant outcomes | 45.5% (5) | 36.4% (4) | 18.2% (2) | 2
Q29. Studies comparing outcomes for mother and infant in settings where physicians are “immediately available” vs. settings where physicians are “readily available” | 70.0% (7) | 10.0% (1) | 20.0% (2) | 5
Q30. Comparison of risk of maternal or infant adverse outcomes during childbirth in general vs. TOL or ERCD | 30.0% (3) | 50.0% (5) | 20.0% (2) | 2
Q31. Studies to compare impact of TOL vs. ERCD on breastfeeding initiation and continuation | 10.0% (1) | 50.0% (5) | 40.0% (4) | 1
Q32. Studies to compare impact of TOL vs. ERCD on psychosocial outcomes such as maternal-infant bonding and post-partum depression | 30.0% (3) | 40.0% (4) | 30.0% (3) | 0
Q33. Surveillance to determine long-term maternal and infant clinical outcomes of TOL vs. ERCD | 60.0% (6) | 30.0% (3) | 10.0% (1) | 4

ERCD, elective repeat cesarean delivery; OB/GYN, obstetrician/gynecologist; TOL, trial of labor; VBAC, vaginal birth after cesarean

a Bolded questions denote those that were selected as a Top 15 research priority in phase 2, round 1.

In order to come to a more definitive consensus on the top 10 research priorities, in a second round stakeholders were asked to rank the top 10 research priorities from the 15 highest priority areas generated in round 1 (top 15 priorities are bolded in Table 4 above and listed in Appendix E). Respondents were instructed to reflect on the topics they believed were the highest priority, both in terms of potential impact and urgency, and to rank them from 1 to 10, with 1 being the most important. The bottom five priorities did not receive a ranking. A weighted score was calculated for each area, with higher rankings given greater weight than lower rankings (i.e., 1=10 points, 2=9 points, 3=8 points, 4=7 points, 5=6 points, 6=5 points, 7=4 points, 8=3 points, 9=2 points, 10=1 point, not ranked=0 points). Using this system of tabulation, a final ranked list emerged (Table 5).

Table 5 Phase 2, Delphi round 2: top 10 VBAC future research priorities

Priority | Final Rank | Weighted Score^a^ | Category of Research
Studies to test clinical, institutional, or policy interventions to increase access to “safe” TOL | 1 | 72 | A
Research on barriers to providing safe TOL, including factors that limit hospitals' ability to meet the “immediately available” requirement (i.e., availability of anesthesiologists, obstetric providers, and other resources) | 2 | 51 | A
Studies comparing outcomes for mother and infant in settings where physicians are “immediately available” vs. settings where physicians are “readily available” | 3 | 46 | A
Studies to understand best practice models based on institutions that are currently offering safe TOL | 4 | 41 | A
Development of standardized measures for short-and long-term maternal and infant outcomes | 5 | 41 | B
Surveillance to determine long-term clinical outcomes of TOL vs. ERCD | 6 | 38 | B
Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | 7 | 37 | C
Clinical and policy relevant studies to address the threat of legal liability on practice patterns regarding TOL vs. ERCD | 8 | 34 | A
Development/utilization of a reliable model or tool to predict the probability of successful VBAC for individual women and/or a tool to predict probability of successful VBAC in general | 9 | 32 | B
Studies to refine, validate, and implement informed consent templates that are informative, reliable, and able to be well documented | 10 | 26 | C

ERCD, elective repeat cesarean delivery; TOL, trial of labor; VBAC, vaginal birth after cesarean

a Weighted scores correspond to the prioritized ranking in the second round of phase 2

## Research Needs

The top 10 research questions arising from the phase 2 prioritization are listed in Table 5. The identified research priorities clustered into three overarching categories: health systems and contextual issues (category A in Table 5), standardized measurement and collection of data on maternal and infant outcomes (category B in Table 5), and understanding how patients perceive risk and how best to communicate risk of mode of delivery after prior cesarean (category C in Table 5). In synthesizing the results it is helpful to discuss each topic in the context of these categories. A brief discussion of each research priority is included in the text below. Potential study designs and information about ongoing and completed research in each area are listed in Table 6.

Table 6 Future research agenda for vaginal birth after cesarean

Ranked Priority | Research Area | Potential Study Designs | Ongoing Research^a^ | Completed Research^a^
Research Area A. Health systems and contextual issues
1 | Studies to test clinical, institutional, or policy interventions to increase access to “safe” TOL after cesarean | Exploratory, descriptive and causal studies, including:; - Analysis of observational data; - Policy case studies^b^; - Surveys of clinicians, policymakers and administrators; - Focus groups/interviews; - Natural experiments or ecological studies among communities with differing medical resources/settings; Once there is a body of evidence on the efficacy of different interventions, experimental studies could be conducted to test their effectiveness in different settings and/or compare the effectiveness of different interventions | | 9, 17, 18
2 | Research on barriers to providing safe TOL, including factors that limit the ability of hospitals to meet the “immediately available” requirement | Exploratory, descriptive and causal studies, including:; - Analysis of observational data; - Policy case studies^b^; - Surveys of clinicians, policymakers, and administrators; - Focus groups/interviews; - Natural experiments or ecological studies among communities with differing medical resources/ settings | 12
3 | Studies comparing outcomes for mother and infant in settings where physicians are “immediately available” vs. settings where physicians are “readily available” | Exploratory, descriptive and causal studies, including:; - Analysis of observational data; - Policy case studies^b^; - Focus groups/interviews; - Surveys of patients, clinicians, and administrators; - Natural experiments or ecological studies among communities with differing medical resources/ settings | | 19
4 | Development of best practice models based on institutions that are currently offering safe TOL | Exploratory and descriptive studies, including:; - Analysis of observational data; - Policy case studies^b^; - Surveys of clinicians, policymakers and administrators; - Focus groups/interviews
8 | Clinical and policy-relevant studies to address the threat of legal liability on practice patterns regarding TOL vs. ERCD | Exploratory, descriptive and causal studies, including:; - Analysis of observational data; - Policy case studies^b^; - Surveys of clinicians, policymakers and administrators; - Focus groups/interviews; - Natural experiments or ecological studies among communities with differing medical resources/settings; - Meta-analysis of observational data | 13 | 19, 20
Research Area B. Standardized measurement and collection of data
5 | Development of standardized measures for short- and long-term maternal and infant outcomes | Exploratory and descriptive studies, including:; - Analysis of observational data; - Reviews, case reports; - Focus groups/interviews with administrators, clinicians and patients; Research should also investigate measures to capture systems and process factors that contribute to safety and quality to inform research gaps outlined in priorities 1-4 | | 19, 21
6 | Surveillance to determine long-term clinical outcomes of TOL vs. ERCD | Descriptive studies, including:; - Analysis of observational data; - Cohort studies; - Analysis of registry data; Development of standardized measures described in priority 5 will facilitate the collection of the most appropriate clinical outcomes as well as process and systems indicators of quality and safety | 14, 15 | 22-25
9 | Development/utilization of a reliable model or tool to predict the probability of successful VBAC for individual women | Descriptive and causal studies, including:; - Analysis of observational data; - Meta-analysis of observational data; - Modeling
Research Area C. Understanding and communicating risk of TOL after cesarean vs. ERCD
7 | Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | Exploratory, descriptive and causal studies, including:; - Focus groups/interviews of patients; - Surveys of patients and providers; - Development of decision aids; - Randomized trials to test different types of decision aids | 16, 26
10 | Studies to refine, validate, and implement informed consent templates that are informative, reliable, and able to be well documented | Exploratory, descriptive and causal studies, including:; - Focus groups/interviews; - Surveys of patients, clinicians, administrators, liability companies; - Randomized trials to test informed consent templates | | 27

a Numbers indicate citations (see Reference section) of ongoing/completed research since the evidence review in 2010.

b Whereas a case study in clinical research describes an individual patient or case, the unit of analysis for a case study in policy research is an institution, a state or even an entire country and the outcome is the impact upon a population. In order clearly to make this distinction, we refer to the latter as “policy case studies.”

ERCD, elective repeat cesarean delivery; SES, socioeconomic status; TOL, trial of labor; VBAC, vaginal birth after cesarean

Overall, stakeholders felt that defining what constitutes a “safe” TOL after cesarean, and a safe birth in general, at the level of the individual, the provider, and the institution or setting of care was important across all top priority research needs. As summed up by one of our stakeholders: “An important potential dilemma is defining what constitutes ‘safe’ TOL, in whose judgment is TOL ‘safe’ and where the ‘immediately available’ standard fits in that definition or if it even is an appropriate factor in the definition. Once safe is defined, find best practices [for] achieving it and test them in other settings.”

### Health Systems and Contextual Issues

#### Priority 1 Studies to test institutional or policy interventions to improve safety and availability of TOL after cesarean

In-depth interviews with stakeholders and review of the literature revealed that very little is known about what constitutes a safe environment for TOL after cesarean (the pros and cons of different settings and environments) and what institutional or policy interventions and/or best practices might contribute to the creation of a safe environment.9 Stakeholders also highlighted the need for research on whether the same types of interventions are applicable among different types of providers or in different institutional settings.

“…the epidemiology of VBAC at this point is well known…it couldn't be more consistent….we don't need any more [epidemiological] studies…. We've got enough…so I think at this point it's about health care services… and outcomes research and trying to figure out how services…can be effectively disseminated to the community, be made available to women and made available in such a way that women are actually receiving the health care that they desire.”

#### Priority 2 Research on barriers to providing safe TOL after cesarean, including factors that limit the ability of hospitals to meet the “immediately available” requirement (i.e., availability of anesthesiologists, availability of obstetric providers, and availability of other resources)

Stakeholders frequently mentioned the “immediately available” phrase from the American Congress of Obstetricians and Gynecologists (ACOG) guideline, which states that “because of the risks associated with TOL after cesarean and that uterine rupture and other complications may be unpredictable, the College recommends that TOL after cesarean be undertaken in facilities with staff immediately available to provide emergency care.”10 Stakeholders suggested that an inability of hospitals to meet the “immediately available” requirement is one of the primary barriers to offering access to safe TOL after cesarean. In addition to the immediate availability of obstetric providers, the availability of anesthesiologists was pinpointed as a critical barrier. Many stakeholders also discussed the fact that there is wide variation in the way that different institutions interpret the meaning of “immediately available.” For example, there is little evidence regarding how rural hospitals manage VBAC risk in cases where a shortage of anesthesiologists limits the ability to provide around-the-clock “immediately available” staff. Stakeholders highlighted the need for further exploration into how the “immediately available” requirement is understood and implemented, barriers to achieving this standard, and other obstacles to providing access to safe TOL.

“It's important! We need to focus on the requirements for the ‘team’ not ‘just’ the provider, including how the finances could work.”

“I also feel that the other important issue is how hospitals are interpreting ‘immediately available.’ I've had small hospitals in my State retain VBAC while larger ones stopped doing it and so feel that the issue has never strictly been one of resource allocation. Is having an OB across the street from the hospital conducting his/her office hours ‘immediate’? Is having one asleep in the doctor's sleeping lounge one floor above the L&D unit enough? Never in my doula work have I witnessed an OB or anesthesiologist standing guard outside of a laboring woman's hospital room in order to be ‘immediately available’ in case of an emergency.”

#### Priority 3 Studies comparing outcomes for mother and infant in settings with “immediately available” compared with “readily available” providers

As mentioned above, stakeholders recognized the “immediately available” requirement as a critical barrier to offering TOL after cesarean. Yet they also pointed to the lack of evidence on the difference in outcomes for mothers and babies in settings where providers are “immediately” compared with “readily” available. To facilitate such this type of research, stakeholders emphasized the need to correlate data on maternal and infant outcomes with hospital level indicators including hospital size, staffing structures, facility resources and capacity, participation in hospital systems and networks, business models, malpractice insurance and carrier restrictions.9 In the words of one of our stakeholders:

“….this would be a very critical study since most hospitals are influenced by ACOG's guidelines. If research finds that outcomes are the same, there would be no basis to support ACOG's requirement. Risk managers and insurance companies would still need ACOG to revise their guidelines.”

#### Priority 4 Studies to understand best practice models for safe TOL after cesarean

Stakeholders reported a number of examples of institutions that are successfully providing access to safe TOL after cesarean. They pointed to a need for in-depth studies of what factors enabled these institutions to provide safe TOL after cesarean and what aspects of their practices can be replicated in other settings as well as a comparison of best practices in a variety of settings and hospital types. In particular, stakeholders suggested developing best practice models for institutions that “do not meet the immediately available guideline,” and stratifying best practice models by hospital size.

#### Priority 8 Clinical- and policy-relevant studies to address the threat of legal liability on practice patterns regarding TOL compared with ERCD

There was wide consensus among the stakeholders interviewed that legal liability is a key driver of the decision to offer TOL after cesarean at both the institutional and provider levels. The perceived risk of malpractice claims and lawsuits are thought to influence clinician behavior, particularly related to cesarean section. Stakeholders highlighted the need for more reliable data to examine the extent that liability concerns are driving practice at both the institutional and provider level.

“It is widely assumed that the VBAC problem will not be resolved without liability reform. It would be useful to get more good data on the real extent to which litigation fears drive provider/hospital choices….if it could be documented that these fears are a main factors, this can support reform efforts. If it is found that they're not really the heart of the problem, the myth can be debunked and efforts redirected.”

“But what isn't an urban myth, but is the more sort of fuzzy thing, is the sense that it is taking on a professional liability burden and that even if you undertake a trial of labor and kind of do all the right things, if there's a bad outcome, that you may be sued for that….”

### Standardized Measurement and Collection of Data on Maternal and Infant Outcomes

#### Priority 5 Development of standardized measures for short- and long-term maternal and infant outcomes

Integral to future decisionmaking at all levels is identification of the most meaningful short-and long-term maternal and infant outcomes and agreement on clear and precise definitions and methods of ascertainment. Stakeholders identified the importance of standardization of definitions as well as methods for measuring and reporting. In addition, as highlighted above further data collection at the hospital level is required in order to develop a more comprehensive understanding of the impact of institutional structure and management on maternal and infant outcomes.

“This is the foundation of all future decisionmaking. Number one priority!”

#### Priority 6 Surveillance to determine long-term clinical outcomes of delivery after previous cesarean

Most studies focus on short- rather than long-term complications of delivery after previous cesarean. Better understanding of the long-term outcomes comparing TOL with ERCD is needed, particularly in order to inform women's choices—especially among those who will have future pregnancies. Women who have a cesarean delivery have an increased risk of a range of chronic conditions and may be at increased risk for infertility or subfertility. Women who undergo multiple cesarean deliveries have a higher risk of morbidity and mortality from placenta accreta.11

In addition, future studies should include a range of reproductive outcomes, including postpartum depression and quality of life. Outcomes that affect both mother and infant, such as those related to breastfeeding and parental attachment, have not been studied in relation to VBAC.

“Clearly needed, especially long-term outcome data.”

“Include maternal information on future pregnancies.”

#### Priority 9 Development/utilization of a reliable model or tool to predict probability of successful VBAC for individual women

The 2010 evidence review identified gaps in the ability of existing prediction tools to select women for a successful TOL after cesarean. Improvements in current prediction tools could be made, which necessitates the collection of standardized data and development of a better understanding of what factors contribute to the probability of a successful TOL in different settings. Prediction tools should be designed to encompass nonmedical factors associated with a successful or failed TOL, the impact of different labor management strategies (such as induction of labor), and whether there are differences among racial, ethnic, or socioeconomic groups.

“This could be used to improve risk stratification, which is a promising candidate for ‘best practice.’”

“The proposed model would not be accurate since what we see from the consumer side is the probability of success being vastly dependent on the type of care provider the woman uses (midwife vs. OB) and birth location.”

### Understanding How Patients Perceive Risk and How Best To Communicate Risk of Mode of Delivery After Prior Cesarean

#### Priority 7 Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL compared with ERCD

Stakeholders identified patient decisionmaking on route of delivery after cesarean as a particular challenge, especially given the recommendation of the 2010 ACOG guidelines that women are engaged in a shared decisionmaking process. In addition to considering the short- and long-term benefits and risks of route of delivery for their current and future pregnancies, patients are also influenced by family obligations, costs, societal norms, and regional availability of options. Stakeholders described an overall lack of understanding how patients are making decisions about TOL compared with ERCD, how they perceive the risks of TOL compared with ERCD, and how their perception of risk influences their decision. They emphasized the need for a more complete and nuanced understanding of how best to present information so that women can make a truly informed choice that incorporates their preferences.

“Need pictures, visible info—patients forget what you tell them in an office visit. Need something they can take home, or do on Web….”

“I regard the entire risk assessment/understanding/communication aspect [as] highly important. Especially for patients and providers, less so for administrators and liability companies.”

“We have no idea about how women actually make this decision. We have no idea. You [need to] know…what they value…their ways to assess…different health states and health processes and how women value what they incorporate. For that woman who chooses a trial of labor, why does she do that? Why does one woman choose it at a 1 in 300 chance or a perceived 1 in 1,000 chance of [harms]… why does one woman look at one in a thousand and think that's crazy and another woman look at a 1 in 1,000 risk of perinatal harm and think, ‘oh, why are you even talking to me about something that's so rare?’ Or two women with a 70 percent chance of success, one chooses an elective repeat and one chooses a trial of labor? I mean what [factors] are driving their decisions? What do they value? We have no idea.”

#### Priority 10 Studies to refine, validate and implement informed-consent templates that are informative, reliable, and able to be well documented

In addition to studies of how women perceive risk and how they make decisions regarding TOL after cesarean, stakeholders prioritized further exploration of how best to ensure detailed and truly informed consent. Because providers differ in their perception of the risk of TOL after cesarean and the actual risk and benefit profile differs for individual women, ensuring truly informed consent is a complex task. In addition, clinicians emphasized the need for a standardized way of providing informed consent endorsed by ACOG or another institutional body. However, stakeholders also pointed out that in addition to developing standardized informed consent templates, there also needs to be agreement on the part of liability companies that evidence of informed consent would be considered in liability cases.

“That would be great to have a national standard. Something ‘blessed’ by ACOG would be great.”

“I would give this a higher priority if the liability companies indicate that this would be of benefit to them. What we hear physicians stating is that having a signed consent form ‘doesn't matter anyways’ when it comes to being sued.”

## Future Research Agenda: Potential Study Designs and Ongoing or Recently Completed Research

Table 6 lists the top 10 future research priorities identified by stakeholders along with suggestions for potential study designs and references to ongoing and completed research relevant to each topic. Potential study designs for each priority area were derived from discussions with stakeholders during semistructured interviews conducted in phase 1 and further developed and informed by research design principles. The suitability of a research design for a research topic depends on a number of factors, including the intent and objectives of the research, how much is already known about the topic in question, and the desired balance between a controlled versus “real world” setting. As evidence in a body of research is gathered, research designs generally progress along a continuum from exploratory to descriptive to causal (or experimental). For example, when little is known about a given topic, exploratory studies are employed to provide insight, increase our understanding of relevant variables and explore and develop hypotheses. Once a body of exploratory research is established, descriptive studies based on observational data provide a map of the patterns and relationships among key variables in a larger context. Next, causal or experimental research attempts to uncover cause and effect relationships by manipulating key independent variables either through investigator controlled or natural experiments.

Because this future research needs agenda extends beyond traditional clinical research into health systems and policy, we expand the nomenclature used to describe potential study designs to include behavioral and policy research in addition to clinical and health services research. A notable distinction in the study design nomenclature in clinical versus policy research is the use and understanding of the term case study. A case study in clinical research describes a study or report of individual patient or case. In contrast, the unit of analysis for a case study in policy research can be an institution, a state or even an entire country as the case refers to a case of policy and the outcome is the impact upon a population. In order clearly to make this distinction, we refer to the latter as “policy case studies” in Table 6.

We identified 98 ongoing or recently completed studies related to VBAC since the publication of the evidence review in 2010, through a search of clinical trial registries, grant databases, and individual funders' Web sites (see Methods: Identification of Ongoing Studies). Few of the ongoing studies related to VBAC addressed the priority research areas identified by stakeholders. Among these, only six ongoing studies were identified that inform at least one of the top 10 prioritized topics. Two studies addressed the health systems issues. In particular, a Dutch study12 assessed barriers to the implementation of TOL, and a study by Roth13 explored the threat of legal liability on practice patterns regarding TOL compared with ERCD (research area A). Two studies evaluated long-term clinical outcomes of TOL compared with ERCD (research area B).14,15 In addition, two studies investigated patient preferences and decisionmaking, information that may add to our understanding of how patients understand risk, and how best to communicate risks of TOL compared with ERCD (research area C).16