# References

1 Hamilton BE, Martin JA, Ventura SJ. Births: Preliminary data for 2010. Natl Vital Stat Rep. 2011;60(2). www.cdc.gov/nchs/data/nvsr/nvsr60/nvsr. January 9, 2012.
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: Final data for 2007. Natl Vital Stat Rep. 2010;58(24). www.cdc.gov/nchs/products/nvsr.htm.
3 National Institutes of Health Consensus Development Conference Statement. Vaginal Birth After Cesarean: New Insights, March 8-10, 2010. Obstet Gynecol. Jun. 2010;115(6):1279-95. [pmid: 20502301].
4 McMahon M, Luther E, Bowes W, et al. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. [pmid: 8703167].
5 Guise JM, Eden K, Emeis C, et al. Vaginal birth after cesarean: new insights. Evid Rep Technol Assess (Full Rep). Mar. 2010;(191):1-397. [pmid: 20629481].
6 Caron A, Neuhauser D. The effect of public accountability on hospital performance: trends in rates for cesarean sections and vaginal births after cesarean section in Cleveland, Ohio. Qual Manag Health Care. 1999;7(2):1-10. [pmid: 10346457].
7 Macones GA. Clinical outcomes in VBAC attempts: what to say to patients?. Am J Obstet Gynecol. Jul. 2008;199(1):1-2. [pmid: 18585519].
8 Sinha IP, Smyth RL, Williamson PR. Using the Delphi technique to determine which outcomes to measure in clinical trials: recommendations for the future based on a systematic review of existing studies. PLoS Med. 2011;8(1):e1000393. [pmid: 21283604].
9 Korst LM, Gregory KD, Fridman M, et al. Nonclinical factors affecting women's access to trial of labor after cesarean delivery. Clin Perinatol. Jun. 2011;38(2):193-216. [pmid: 21645789].
10 Practice bulletin no. 115: Vaginal birth after previous cesarean delivery. Obstet Gynecol. Aug. 2010;116(2 pt 1):450-63. [pmid: 20664418].
11 Signore C, Spong CY. Vaginal birth after cesarean: new insights manuscripts from an NIH Consensus Development Conference, March 8-10, 2010. Semin Perinatol. Oct. 2010;34(5):309-10. [pmid: 20869544].
12 Maastrict University Medical Center. Current Dutch practice on caesarean sections: Identification of barriers and facilitators for optimal care (SIMPLE). Bethesda (MD). National Library of Medicine (U.S.). August 23, 2011. Available from: clinicaltrials.gov/ct2/show/NCT01261676.
13 Roth L. Legal and insurance environments impact and health practices (abstract). University of Arizona. Award Number 0958190. 2010. June. 2.
14 Chinese University of Hong Kong. Vaginal birth after caesarean section - effect on maternal psychosocial function. Bethesda (MD). National Library of Medicine. clinicaltrials.gov/ct2/show/NCT00294411. August 23, 2011.
15 University of British Columbia. Impact of doula support on childbirth outcomes for women undergoing a vaginal birth after cesarean (VBAC). Bethesda (MD). National Library of Medicine. clinicaltrials.gov/ct2/show/NCT01216098. August 23, 2011.
16 Taipei Medical University WanFang Hospital. Exploring Taiwanese womens' decision-making regarding vaginal birth after caesarean section. Bethesda (MD). National Library of Medicine. clinicaltrials.gov/ct2/show/NCT01210300. August 23, 2011.
17 Leeman LM, King VJ. Increasing patient access to VBAC: New NIH and ACOG recommendations. Am Fam Physician. 2011;83(2):121-7. [pmid: 21243986].
18 Scott JR. Solving the vaginal birth after cesarean dilemma. Obstet Gynecol. 2010;115(6):1112-3. [pmid: 20502277].
19 Go MD, Emeis C, Guise JM, et al. Fetal and neonatal morbidity and mortality following delivery after previous cesarean. Clin Perinatol. 2011;38(2):311-9. [pmid: 21645798].
20 Bonanno C, Clausing M, Berkowitz R. VBAC: a medicolegal perspective. Clin Perinatol. 2011;38(2):217-25. [pmid: 21645790].
21 Cheng YW, Eden KB, Marshall N, et al. Delivery after prior cesarean: maternal morbidity and mortality. Clin Perinatol. 2011;38(2):297-309. [pmid: 21645797].
22 Keirse MJ. Home birth: gone away, gone astray, and here to stay. Birth. 2010;37(4):341-6. [pmid: 21083728].
23 King TL. Can a vaginal birth after cesarean delivery be a normal labor and birth? Lessons from midwifery applied to trial of labor after a previous cesarean delivery. Clin Perinatol. 2011;38(2):247-63. [pmid: 21645793].
24 Grivell RM, Dodd JM. Short- and long-term outcomes after cesarean section. Expert Review of Obstetrics and Gynecology. 2011;6(2):205-15.
25 Grivell RM, Barreto MP, Dodd JM. The influence of intrapartum factors on risk of uterine rupture and successful vaginal birth after cesarean delivery. Clin Perinatol. 2011;38(2):265-75. [pmid: 21645794].
26 Oregon Health & Science University. Measuring preferences for childbirth after cesarean. Bethesda (MD). National Library of Medicine (U.S.). August 23, 2011. Available from: clinicaltrials.gov/ct2/show/NCT00267735.
27 Chervenak FA, McCullough LB. An ethical framework for the informed consent process for trial of labor after cesarean delivery. Clin Perinatol. 2011;38(2):227-31. [pmid: 21645791].
28 MacDorman M, Declercq E, Menacker F. Recent trends and patterns in cesarean and vaginal birth after cesarean (VBAC) deliveries in the United States. Clin Perinatol. 2011;38(2):179-92. [pmid: 21645788].