# Introduction

The rate of cesarean delivery in the United States increased dramatically over the past 2 decades, from 20.7 percent in 1996 to 32.9 percent in 2010.^1^ Part of the reason for the increase is a decline in the rate of vaginal birth after cesarean (VBAC).2 Although the dictum “once a cesarean, always a cesarean” guided clinical practice for a good part of the 20^th^ century, a 1980 National Institutes of Health (NIH) Consensus Development Conference Panel recognized trial of labor (TOL) after prior cesarean as a viable option for certain low-risk women.3 An increase in VBAC ensued; by 1996, more than 28 percent of women with a prior cesarean delivered vaginally.2 However, a number of medical and nonmedical factors, including reports in the 1990s of an increased risk of maternal complications with TOL compared with elective repeat cesarean, pushed the pendulum in the opposite direction.3,4 The percentage of women with a previous cesarean delivering vaginally fell from a peak of 28 percent in 1996 to 8.5 percent in 2007.^2^

In 2010, the NIH again convened a Consensus Development Conference Panel to evaluate the growing body of evidence on the clinical risks and benefits of TOL after cesarean.3 In preparation for the 2010 conference the Agency for Healthcare Research and Quality (AHRQ) commissioned the Oregon Evidence-based Practice Center (EPC) to conduct a review of the evidence on a number of emerging issues related to VBAC,3 which was released as AHRQ Evidence Report/Technology Assessment Number 191.^5^ The evidence review addressed the following six Key Questions.

1. What are the rates and patterns of utilization of trial of labor after prior cesarean, vaginal birth after cesarean, and repeat cesarean delivery in the United States?
2. What are the nonmedical factors (e.g., provider type, hospital type) that influence the patterns and utilization of trial of labor after prior cesarean?
3. Among women who attempt a trial of labor after prior cesarean, what are the vaginal delivery rate and the factors that influence it?
4. What are the short- and long-term benefits and harms to the mother of attempting trial of labor after prior cesarean compared with elective repeat cesarean delivery, and what factors influence benefits and harms?
5. What are the short- and long-term benefits and harms to the baby of maternal attempt at trial of labor after prior cesarean compared with elective repeat cesarean delivery, and what factors influence benefits and harms?
6. What are the critical gaps in the evidence for decisionmaking, and what are priority investigations needed to address these gaps?

Figure 1 presents the analytic framework incorporating information on the population, interventions, comparators, and outcomes (PICO) that pertain to all six review questions.

Figure 1 Original analytic framework from evidence review

CD = cesarean delivery; ERCD = elective repeat cesarean delivery; IRCD = indicated repeat cesarean delivery; TOL = trial of labor; UR = uterine rupture; VBAC = vaginal birth after cesarean

Figure 1 presents the original analytic framework from the evidence review incorporating information on the population, interventions, comparators, and outcomes (PICO) that pertain to all six original review questions. The figure depicts an analytic framework that outlines the population, interventions, and outcomes describing the impact of TOL or ERCD for pregnant women. This figure illustrates intermediate and final outcomes, as well as influences on decisionmaking along the framework. The population includes pregnant women who have had a prior CD. To the right of the population is a box connected by an arrow that lists the intended route of delivery as TOL or ERCD. This is followed by second box with the actual routes of delivery including the interventions: VBAC, assisted spontaneous, ERCD labored, ERCD unlabored, IRCD labored, and IRCD unlabored. A box with intermediate maternal (breast feeding) and infant (Apgar) outcomes follows. Final outcomes include both maternal and infant health outcomes. Influences are depicted at the top of the diagram in a large diamond shaped box that lists the following contextual factors: health care/system and hospital policy, social (including family) environment/setting, and medical/obstetrical conditions (cultural, legal). Finally, an arrow across the bottom of the entire framework links a box labeled future pregnancies from the health outcomes to the population at the beginning of the framework.

While the evidence review addressed all six questions, Key Questions 3-6 were the main focus for presentation at the NIH Conference. One of the major findings of the 2010 evidence review was that the best evidence suggests VBAC is a reasonable and safe choice for the majority of women with prior cesarean. The authors report that maternal and infant mortality for women with prior cesarean is not significantly elevated when compared with overall national rates of mortality in childbirth. Further, the majority of women who undergo TOL after prior cesarean will have a successful VBAC, and they and their infants will be healthy.5 However, the juxtaposition of maternal and fetal risks makes the decision to have a VBAC particularly complicated. The 2010 evidence review reported that maternal mortality is significantly higher for elective repeat cesarean delivery (ERCD)^a^ than for TOL after cesarean (13.4 vs. 3.8 deaths per 100,000).5 On the other hand, although very rare, catastrophic fetal outcomes are more common for TOL after cesarean, with an overall perinatal death rate of 1.3 per 1,000 for TOL after cesarean compared with 0.5 per 1,000 for ERCD.5 To date, sophisticated statistical models for TOL after cesarean have not been able to predict who will do well and who will be harmed.

a Elective repeat cesarean delivery refers to the option of planned repeat cesarean delivery as opposed to attempting a trial of labor. The term elective is meant to distinguish from medically indicated cesarean delivery, which is offered when the health of the mother or infant is at risk. It is important to recognize that elective does not always mean that a woman herself is “choosing” to have a repeat cesarean. In many cases access to TOL after cesarean is limited and many providers are unable to offer this option.

Both the systematic review and the NIH Conference revealed that VBAC rates continue to decline despite evidence supporting this as a safe option. This suggests that contextual and nonmedical factors are major drivers of health care delivery. The review found a paucity of research in these domains (Key Questions 1–2), emphasizing the importance of indepth investigation and development of potential research questions and research designs with key stakeholders.

## Evidence Gaps

Prior to the NIH Conference, external peer reviewers—including representatives of Federal agencies (U.S. Food and Drug Administration, Centers for Disease Control and Prevention, and NIH), maternity and pediatric clinicians, advocacy groups, payers, policymakers, content experts, and researchers—were asked to comment and prioritize research gaps for Key Questions 3-6. Peer reviewers were asked to rate topics as low, medium, or high priority for future research, and to provide additional clarification on their positions. Those areas that were rated as highest priority (with at least 50 percent of experts rating the domain as high) are summarized below.

### Evidence Gaps—Priorities From the 2010 Evidence Review

- Population-level research on patterns of utilization and maternal/infant outcomes of VBAC, TOL with emergent cesarean, and ERCD, stratified by race/ethnicity and socioeconomic status.
- Surveillance to determine important long-term clinical outcomes of VBAC, emergent cesarean, or ERCD.
- Investigation of whether antepartum or intrapartum management strategies—such as induction of labor—influence maternal/infant outcomes and rates of VBAC, TOL with emergent cesarean, and ERCD.
- Effect of cumulative dose and regimen of induction agent (PGE2, oxytocin, etc.) on maternal and infant harms.
- Imaging as a modality to predict uterine rupture or other outcomes.
- Studies that correlate benefits and harms of VBAC, TOL with emergent cesarean, and ERCD with short- and long-term health system costs.
- Clear and precise definitions and measurement of maternal and infant health outcomes associated with the different delivery methods (e.g., VBAC, TOL with emergent cesarean, or ECRD).
- Development of standardized measures for short-and long-term maternal and infant outcomes with VBAC, TOL with emergent cesarean, and ERCD.
  ○ Short term: infection, surgical injury
  ○ Long term: pelvic floor disorders, quality of life
- Studies to compare the impact of VBAC, TOL with emergent cesarean, and ERCD on breastfeeding initiation and continuation.

The 2010 evidence review and the NIH Consensus Development Conference Statement highlighted several nonmedical factors that play an important role in decisionmaking about and access to TOL after cesarean—including professional liability concerns, professional and institutional policies, patient insurance type, and provider and patient attitudes.6,7 As presented at the NIH Conference, many hospitals have chosen either officially or unofficially to ban women who had a previous cesarean from attempting a TOL in subsequent births.7,8 Despite the influence of these factors on decisionmaking and access to TOL, both the 2010 evidence review and the NIH Consensus Statement concluded that data to judge the relative impact and interaction of these factors are lacking and that additional research is warranted. Given few examples of obstetric health care system delivery and contextual research, engaging a broad array of stakeholders to understand the outcomes and design that would be most informative to drive change is important. Accordingly, this Future Research Needs project consists of two phases. In phase 1, we engage a panel of stakeholders to identify the most important research gaps, with a particular focus on potential research questions relating to contextual and nonmedical factors that influence practice patterns. In phase 2, we ask stakeholders to prioritize across all of the six evidence review questions to provide a full spectrum of future research needs.