# Executive Summary

## Background

The rate of cesarean delivery in the United States increased dramatically over the past two decades, from 20.7 percent in 1996 to 32.8 percent in 2010.^1^ Part of the reason for the increase is a decline in the rate of vaginal birth after cesarean (VBAC).2 Although the dictum “once a cesarean, always a cesarean” guided clinical practice for a good part of the 20^th^ century, a 1980 National Institutes of Health (NIH) Consensus Development Conference Panel recognized trial of labor (TOL) after prior cesarean as a viable option for certain low-risk women.3 An increase in VBAC ensued; by 1996, more than 28 percent of women with a prior cesarean delivered vaginally.2 However, a number of medical and nonmedical factors, including reports in the 1990s of an increased risk of maternal complications with TOL compared with elective repeat cesarean, pushed the pendulum in the opposite direction.3,4 The percentage of women with a previous cesarean delivering vaginally fell from a peak of 28 percent in 1996 to 8.5 percent in 2007.^2^

In 2010, NIH again convened a Consensus Development Conference Panel to evaluate the growing body of evidence on the clinical risks and benefits of TOL after cesarean. In preparation for the 2010 conference, the Agency for Healthcare Research and Quality (AHRQ) commissioned the Oregon Evidence-based Practice Center (EPC) to conduct a review of the evidence on a number of emerging issues related to VBAC,3 which was released as AHRQ Evidence Report/Technology Assessment No. 191.^5^ The evidence review addressed the following six Key Questions.

1. What are the rates and patterns of utilization of trial of labor after prior cesarean, vaginal birth after cesarean, and repeat cesarean delivery in the United States?
2. What are the nonmedical factors (e.g., provider type, hospital type) that influence the patterns and utilization of trial of labor after prior cesarean?
3. Among women who attempt a trial of labor after prior cesarean, what are the vaginal delivery rate and the factors that influence it?
4. What are the short- and long-term benefits and harms to the mother of attempting trial of labor after prior cesarean compared with elective repeat cesarean delivery, and what factors influence benefits and harms?
5. What are the short- and long-term benefits and harms to the baby of maternal attempt at trial of labor after prior cesarean compared with elective repeat cesarean delivery, and what factors influence benefits and harms?
6. What are the critical gaps in the evidence for decisionmaking, and what are priority investigations needed to address these gaps?

Figure A presents the analytic framework incorporating information on the population, interventions, comparators, and outcomes (PICO) that pertain to all six Key Questions.

Figure A Original analytic framework from evidence review

CD = cesarean delivery; ERCD = elective repeat cesarean delivery; IRCD = indicated repeat cesarean delivery; TOL = trial of labor; UR = uterine rupture; VBAC = vaginal birth after cesarean

Figure A presents the original analytic framework from the evidence review incorporating information on the population, interventions, comparators, and outcomes (PICO) that pertain to all six original review questions. The figure depicts an analytic framework that outlines the population, interventions, and outcomes describing the impact of TOL or ERCD for pregnant women. This figure illustrates intermediate and final outcomes, as well as influences on decisionmaking along the framework. The population includes pregnant women who have had a prior CD. To the right of the population is a box connected by an arrow that lists the intended route of delivery as TOL or ERCD. This is followed by second box with the actual routes of delivery including the interventions: VBAC, assisted spontaneous, ERCD labored, ERCD unlabored, IRCD labored, and IRCD unlabored. A box with intermediate maternal (breast feeding) and infant (Apgar) outcomes follows. Final outcomes include both maternal and infant health outcomes. Influences are depicted at the top of the diagram in a large diamond shaped box that lists the following contextual factors: health care/system and hospital policy, social (including family) environment/setting, and medical/obstetrical conditions (cultural, legal). Finally, an arrow across the bottom of the entire framework links a box labeled future pregnancies from the health outcomes to the population at the beginning of the framework.

While the evidence review addressed all six questions, Key Questions 3–6 were the main focus for presentation at the NIH Conference. Therefore, prior to the conference, external peer reviewers were asked to comment and prioritize research gaps for Key Questions 3–6. The aim of this Future Research Needs project is to identify and prioritize future research needs addressed in the entire evidence review.

Both the systematic review and the Conference revealed that VBAC rates continued to decline despite evidence supporting VBAC as a safe option. This suggests that the contextual and nonmedical factors in the first two questions are likely major drivers of health care delivery. The review found a paucity of research in these domains (Key Questions 1–2), emphasizing the importance of indepth investigation and development of potential research questions and research designs with key stakeholders. This report therefore generates future research topics for Key Questions 1–2 in order to prioritize across all six Key Questions of the evidence review.

## Methods

A sample of stakeholders with interests in VBAC research—including clinicians, consumer advocates, research funders, researchers, legal/liability representatives, and hospital administrators—were invited to participate in prioritizing a future research agenda for VBAC. Recruitment was conducted from May to June 2011.

In phase 1 we conducted indepth interviews with stakeholders to understand and refine evidence gaps, with a particular emphasis on identifying potential nonmedical and contextual research questions. In phase 2, stakeholders completed two rounds of a Delphi process to identify and rank the top 10 research priorities. The questionnaires were constructed from information gaps identified in the 2010 evidence review, through informational interviews with the lead investigator of the evidence review, and through interviews with stakeholders. Both structured questions and open-ended narrative responses were used to identify high-priority research topics, and those topics were searched in the recent VBAC literature.

For each of the structured questions, stakeholders were asked to indicate whether the topic was low, medium, or high priority for future research and to provide narrative text to indicate additional detail on the types of research they recommended. At the end of the questionnaire, we provided a list of all topics and asked respondents to choose the 10 highest priority areas. In order to come to a more definitive consensus on the top 10 research priorities, in a second round stakeholders were asked to rank order the top 10 research priorities from a list of the 15 highest priority areas identified in round 1. The second prioritization questionnaire was sent electronically to participants on July 26, 2011, and they were asked to complete and return it by August 1, 2011.

Ongoing studies and recently completed research between March 2010 and August 2011 were identified by searching Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, Cochrane Database of Reviews of Effects (DARE), Ovid MEDLINE^®^, Scopus, the Annals of Internal Medicine Web site, Google Scholar, clinical trial registries, grant databases, and individual funders' Web sites.

## Results

We invited 30 stakeholders to participate in the phase I semistructured interviews, and of those 16 agreed to participate. Overall, we conducted individual or group interviews with 6 of the 6 legal/liability or hospital administrator stakeholders (100 percent), 2 of the 6 patient/consumer advocates (33 percent), 5 of the 13 clinicians (30 percent), 1 of the 2 researchers (50 percent), and 2 of the 3 research funders (66 percent). We categorized the identified research areas into four overarching themes: health systems (9 questions); risk, attitudes, and decisionmaking (7 questions); shared decisionmaking and informed consent (5 questions), and maternal and infant outcomes (12 questions). These four categories included the gaps identified during the 2010 evidence review as well as those identified during the semistructured interviews in phase 1.

We invited 11 stakeholders to participate in the phase 2 Delphi process. In compliance with Federal guidelines, only nine of the stakeholders were not Federal employees. All 11 stakeholders invited to participate in phase 2 completed the first questionnaire, and 10 of the 11 completed the second questionnaire (81 percent). Of the stakeholders who participated in phase 2 one was a hospital administrator, two were patient/consumer advocates, five were clinicians, one was a researcher, and two were research funders. A list of the top 10 research priorities was developed.

The top 10 research questions arising from the phase 2 prioritization are listed in Table A. The research priorities identified cluster into three overarching categories: health systems and contextual issues (category A), standardized measurement and collection of data on maternal and infant outcomes (category B), and understanding how patients perceive risk and how best to communicate risk of mode of delivery after prior cesarean (category C). In synthesizing the results, it is helpful to discuss each topic in the context of these categories.

Table A Phase 2, Delphi round 2: Top 10 VBAC future research priorities

Priority | Final Rank | Weighted Score^a^ | Category of Research
Studies to test clinical, institutional, or policy interventions to increase access to “safe” TOL | 1 | 72 | A
Research on barriers to providing safe TOL, including factors that limit hospitals' ability to meet the “immediately available” requirement (i.e., availability of anesthesiologists, obstetric providers, and other resources) | 2 | 51 | A
Studies comparing outcomes for mother and infant in settings where physicians are “immediately available” vs. settings where physicians are “readily available” | 3 | 46 | A
Studies to understand best-practice models based on institutions that are currently offering safe TOL | 4 | 41 | A
Development of standardized measures for short- and long-term maternal and infant outcomes | 5 | 41 | B
Surveillance to determine long-term clinical outcomes of TOL vs. ERCD | 6 | 38 | B
Research on how patients understand risk, how they respond to different ways of framing risk, and how best to communicate risks of TOL vs. ERCD | 7 | 37 | C
Clinical and policy-relevant studies to address the threat of legal liability on practice patterns regarding TOL vs. ERCD | 8 | 34 | A
Development/utilization of a reliable model or tool to predict the probability of successful VBAC for individual women and/or a tool to predict probability of successful VBAC in general | 9 | 32 | B
Studies to refine, validate, and implement informed-consent templates that are informative, reliable, and able to be well documented | 10 | 26 | C

ERCD = elective repeat cesarean delivery; TOL = trial of labor; VBAC = vaginal birth after cesarean. Categories of research: A = health systems and contextual issues; B = standardized measurement and collection of data on maternal and infant outcomes; C = understanding how patients perceive risk and how best to communicate risk of mode of delivery after prior cesarean.

a Weighted scores correspond to the prioritized ranking in the second round of phase 2.

Within the category of contextual or health systems factors (A), stakeholders felt it was important to study institutional and systems-level barriers and facilitators to providing and delivering safe trials of labor after cesarean, including how the “immediately available” requirement is understood and implemented, and concerns about legal liability. (The “immediately available” phrase is from the American Congress of Obstetricians and Gynecologists [ACOG] guideline, which states that “because of the risks associated with TOL after cesarean and that uterine rupture and other complications may be unpredictable, the College recommends that TOL after cesarean be undertaken in facilities with staff immediately available to provide emergency care”.6) In the words of one of our stakeholders, “The epidemiology of VBAC at this point is well known…it couldn't be more consistent….We don't need any more [epidemiological] studies….We've got enough…so I think at this point it's about health care services… and outcomes research and trying to figure out how services…can be effectively disseminated to the community, be made available to women, and made available in such a way that women are actually receiving the health care that they desire.”

Within the category of standardized measurement and collection of data on maternal and infant outcomes (B), stakeholders emphasized the importance of agreement on clear and precise definitions and methods of ascertainment both within and across hospitals. In addition to measures of both short- and long-term clinical outcomes, stakeholders highlighted the need for measures of psychosocial factors such as post partum depression, quality of life, breastfeeding initiation, and maternal-infant bonding. Stakeholders also prioritized further data collection at the hospital level in order to develop a more comprehensive understanding of the impact of institutional structure and management on maternal and infant outcomes.

With regard to the third category, understanding how patients perceive risk and how best to communicate risk of mode of delivery after prior cesarean (C), stakeholders expressed uncertainty about how patients perceive the risks of TOL compared with elective repeat cesarean delivery (ERCD), how best to frame and communicate the risks of TOL compared with ERCD, and the most effective way to present information so that women can make an informed choice that incorporates their preferences. This was felt to be particularly important given the 2010 ACOG guidelines, which state that “after counseling, the ultimate decision to undergo TOL after cesarean or a repeat cesarean delivery should be made by the patient in consultation with her health care provider.”6

Overall, stakeholders felt that defining what constitutes a “safe” TOL after cesarean, and a safe birth in general, at the level of the individual, the provider, and the institution or setting of care was important across all top priority research needs. As summed up by one of our stakeholders: “An important potential dilemma is defining what constitutes ‘safe’ TOL, in whose judgment is TOL ‘safe’ and where the ‘immediately available’ standard fits in that definition or if it even is an appropriate factor in the definition. Once safe is defined, find best practices [for] achieving it and test them in other settings.”

## Discussion

Half of the top 10 priorities for future research on VBAC fall in the category of health systems or contextual issues, a nascent field of research. As indicated in the evidence review, the ability to conduct large-scale studies in this area relies on the development of a standard terminology and documentation of process measures that accurately reflect the conduct of labor and delivery across a range of settings. Although childbirth is the leading reason for hospital admission in the United States, obstetric data systems both within and across hospitals “remain rudimentary and lack standardization.”7 While interest in measuring the quality of obstetric care is growing, to date there is no clear consensus as to what quality measures are most important to inform clinical decisionmaking and improve obstetric practices. Interestingly, even for the areas with more robust literature, such as maternal and infant health outcomes associated with TOL compared with ERCD, the development of standard terminology is a recognized deficiency that has yet to be fully addressed. The move from paper charts to the increasingly widespread use of electronic medical records provides a valuable opportunity to document and collect information on quality and safety both within and across hospitals, facilitating the development of best practices that can be replicated in a variety of settings.

Our research methodology has some limitations that deserve discussion. First, although the phase 2 Delphi questionnaire included a range of issues beyond health systems, the initial focus on questions about contextual and health systems factors during the semistructured interviews in phase 1 could have primed the respondents to rank these items higher during the phase 2 prioritization. Second, the small sample size of our stakeholder panel limits the generalizability of our findings. Finally, although every attempt was made to engage a balanced group of stakeholders, the group of clinicians was slightly larger than the other stakeholder groups in order to include the perspectives of physicians, midwives, and nurse practitioners.

## Conclusion

The top 10 future research needs as prioritized by stakeholders fall into three overarching categories: health systems and contextual issues (category A), standardized measurement and collection of data on maternal and infant outcomes (category B), and understanding and communicating risk of mode of delivery after prior cesarean (category C). Within category A, stakeholders felt it was important to study institutional and systems-level barriers and facilitators to providing and delivering safe trials of labor after cesarean, including how the “immediately available” requirement is understood and implemented, and concerns about legal liability. Within category B, stakeholders prioritized standardized measurement and collection of data on short-and long-term maternal and infant outcomes and emphasized the importance of agreement on clear and precise definitions and methods of ascertainment both within and across hospitals. With regard to category C, stakeholders prioritized research about how patients perceive the risks of TOL compared with ERCD, how best to frame and communicate the risks of each option, and the most effective way to present information so that women can make an informed choice that incorporates their preferences. Overall, stakeholders felt that defining what constitutes a “safe” TOL after cesarean and safe birth in general, at the level of the individual, the provider, and the institution or setting of care was important across all top priority research needs.

## References

1 Hamilton BE, Martin JA, Ventura SJ. Births: preliminary data for 2010. Natl Vital Stat Rep. 2011;60(2). www.cdc.gov/nchs/data/nvsr/nvsr60/nvsr. January 9, 2012.
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2007. Natl Vital Stat Rep. 2010;58(24). www.cdc.gov/nchs/data/nvsr/nvsr58/nvsr.
3 National Institutes of Health Consensus Development Conference Statement. Vaginal Birth After Cesarean: New Insights, March 8-10, 2010. Obstet Gynecol. Jun. 2010;115(6):1279-95. [pmid: 20502301].
4 McMahon M, Luther E, Bowes W, et al. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-95. [pmid: 8703167].
5 Guise JM, Eden K, Emeis C, et al. Vaginal Birth After Cesarean: New Insights. Evidence Report/Technology Assessment No. 191. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No. 290-2007-10057-I.) AHRQ Publication No. 10-E003. Rockville, MD. Agency for Healthcare Research and Quality. March. 2010.
6 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin No. 115: Vaginal birth after previous cesarean delivery. Obstet Gynecol. Aug. 2010;116(2 pt 1):450-63. [pmid: 20664418].
7 MacDorman M, Declercq E, Menacker F. Recent trends and patterns in cesarean and vaginal birth after cesarean (VBAC) deliveries in the United States. Clin Perinatol. 2011;38(2):179-92. [pmid: 21645788].