# Addendum

August 9, 2012

The authors would like to acknowledge the thoughtful comments that were submitted during the public comment period for the draft report from May 25, 2012 to June 22, 2012. In response, and because future research needs reports are a new addition to the Effective Health Care Program, we offer the following clarifications.

We received comments regarding the challenge of obtaining funding to conduct future research in the areas prioritized by stakeholders (especially research on health systems and contextual factors). The overarching goal of the future research needs reports is to identify research that can fill evidence gaps and is relevant to patients, clinicians and other stakeholders in their real-world decisionmaking. The reports are intended to help researchers and funders of research make well-informed decisions in designing and funding research, thereby improving the quality of health care services delivered.

A concern was raised about the small number of stakeholders engaged in this activity. While we agree that nine or fewer individuals is a small number, we worked within the parameters of the Paperwork Reduction Act that limit the number of participants (other than federal employees). Working within these regulations we made every effort to achieve a balanced distribution of stakeholders (e.g., consumer advocate, clinician, legal liability/hospital administrator, researcher, and research funder) with an emphasis on patient-centered outcomes. Additionally, we looked at the results of the prioritization process based on stakeholder type to explore whether responses might differ by perspective and found that the top 10 priorities were remarkably consistent across stakeholder groups. While we would have appreciated the additional time and opportunity to engage even greater numbers of stakeholders, we took steps to invite representatives from each of the major stakeholder groups interested in vaginal birth after cesarean section, and we did our best to examine the responses both independently and collectively to consider potential differences.

Another comment expressed concern that the Discussion section highlights health systems issues more than patient-oriented outcomes. Stakeholders repeatedly emphasized that external forces (such as hospital policy, liability, and American Congress of Obstetricians and Gynecologists statements) shape the delivery of care and availability of options for individual patients. As the availability of options is a necessary prerequisite to many of the other patient-oriented issues that were prioritized in this project, these health systems issues became a central part of stakeholder discussions and are therefore prominent in the Discussion section of this paper. Among the top 10 future research needs prioritized by stakeholders was patient-oriented research on how women perceive risk, how best to communicate the risks of trial of labor versus elective repeat cesarean delivery, and the standardized measurement and collection of data on short- and long-term outcomes that will better inform women's choices.