# Acknowledgments

We are grateful to the stakeholders who devoted their time to this project and whose participation, expertise, and thoughtful contributions during informational interviews made this report possible. We thank our colleagues at the Oregon Evidence-based Practice Center, the authors of the 2010 evidence report on vaginal birth after cesarean. We appreciate and acknowledge the contributions of the AHRQ Task Order Officer, Christine Chang, M.D., M.P.H. We would like to thank Robin Paynter, M.L.I.S., for conducting the literature searches; Leah Williams, B.S., for editorial support; Katie Reitel, B.A., for administrative support; and Lia LaBrant, M.D., for drafting the initial proposal for this project. Finally, we thank Mark Helfand, M.D., M.P.H., for his insights and continued support.