# Discussion

The purpose of this project was to engage a panel of national stakeholders to identify and prioritize future research needs in the area of vaginal birth after cesarean (VBAC). The 2010 evidence review included an initial prioritization of research gaps for the four Key Questions (Key Questions 3–6) relating to maternal and infant health outcomes. However, because of the limited body of evidence and focus of the Conference on questions 3–6, research gaps relating to the first two questions on practice patterns, trends, and nonmedical factors were not prioritized by the original review. The evidence review and the National Institutes of Health (NIH) Consensus Development Conference Statement identified numerous factors that play an important role in decisionmaking and patient access to trial of labor (TOL) after cesarean—including professional liability concerns, professional and institutional policies, patient insurance type, and provider and patient attitudes.6,7 Yet they found relatively few studies devoted to understanding the influence of such nonmedical factors on the patterns and utilization of VBAC and a limited evidence base from which to prioritize future research in this area.5 Accordingly, in the first phase of this project, we engaged a diverse panel of stakeholders to explore potential research needs for the first two questions relating to nonmedical factors shaping patterns of utilization. In the second phase, we engaged a smaller subset of stakeholders to prioritize potential research questions across all of the six evidence review questions to provide a full spectrum of future research needs relating to VBAC.

Half of the top 10 VBAC future research needs prioritized as important by stakeholders fall into the category of health systems or contextual issues. In the words of one of our stakeholders, “The epidemiology of VBAC at this point is well known…it couldn't be more consistent….We don't need any more [epidemiological] studies…. We've got enough…so I think at this point it's about health care services… and outcomes research and trying to figure out how services…can be effectively disseminated to the community, be made available to women and made available in such a way that women are actually receiving the health care that they desire.” Moreover, stakeholders felt that defining what constitutes a “safe” TOL after cesarean, and a safe birth in general, at the level of the individual, the provider, and the institution or setting of care was an important consideration across all top priority research needs.

There are challenges inherent to conducting research on the role of health systems and contextual factors in the delivery and conduct of maternity care. As highlighted in the National Institutes of Health (NIH) Consensus Development Conference Statement, currently there are few data available to judge the relative impact and interaction of nonmedical factors on decisionmaking about and access to TOL.3 Consequently, initial studies will likely be exploratory and descriptive and may need to rely on nontraditional methods including qualitative interviews, case studies or natural experiments.

Ultimately, the ability to conduct large-scale studies in this area hinges on the development of standard terminology and indicators to measure nonmedical outcomes and process measures that influence TOL decisionmaking and access. Historically, the quest to develop standardized obstetric indicators has not been an easy task. Although childbirth is a leading reason for hospital admission in the United States, obstetric data systems both within and across hospitals “remain rudimentary and lack standardization.”28 It is interesting that even in areas with more robust literature, such as maternal and infant health outcomes, the development of standard terminology is a recognized deficiency that has yet to be addressed. The move from paper charts to the increasingly widespread use of electronic medical records provides a valuable opportunity to document and collect standardized data on maternal and infant outcomes as well as nonmedical and process outcomes both within and across hospitals. The collection of validated outcome measures across time and hospitals would facilitate the development of best practices that can be replicated in a variety of settings. However, the current lack of standardized outcome measures impedes utilizing the full power of this technology and needs to be addressed.

Finally, our research methodology has some limitations that deserve discussion. First, although the phase 2 Delphi questionnaire included a range of issues beyond health systems, the focus on questions about contextual and health systems factors during the semistructured interviews in phase 1 could have primed the respondents to rank these items higher during the phase 2 prioritization. Second, the small sample size of our stakeholder panel limited the ability to examine differences in priorities across stakeholder groups as well as the generalizability of our findings. Finally, because of the small overall sample size, attempts to include a spectrum of clinical maternity care (e.g. physicians, midwives, and nurse practitioners) resulted in the clinician group being larger than the other stakeholder groups.