# Conclusions

The top 10 future research needs as prioritized by stakeholders fall into three overarching categories: health systems and contextual issues (category A), standardized measurement and collection of data on short- and long-term maternal and infant outcomes (category B), and understanding how patients perceive risk and how best to communicate risk of mode of delivery after prior cesarean (category C). Within category A, stakeholders felt it was important to study institutional and systems level barriers and facilitators to providing and delivering safe trials of labor after cesarean, including how the “immediately available” requirement is understood and implemented, and concerns about legal liability. Within category B, stakeholders prioritized standardized measurement and collection of data on short- and long-term maternal and infant clinical and psychosocial outcomes, and emphasized the importance of agreement on clear and precise definitions and methods of ascertainment both within and across hospitals. With regard to category C, stakeholders prioritized research on how patients perceive the risks of trial of labor (TOL) compared with repeat cesarean delivery, how best to frame and communicate the risks of each option, and the most effective way to present information so that women can make an informed choice that incorporates their preferences.