# Search Strategy for Ongoing Studies

## Vaginal Birth After Cesarean: Future Research Needs

Databases and Search Strategies

Name | Date Searched | Platform Provider
Citation Search
Scopus | 08/10/2011 | Elsevier
Medline | 08/10/2011 | OvidSP
Google Scholar | 08/10/2011 | Google
Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, Cochrane Database of Reviews of Effects (DARE) | 08/10/2011 | Cochrane
Grey Literature Databases
AHRQ Gold | 08/25/2011 | http://gold.ahrq.gov/projectsearch/
Foundation Directory Online | 08/31/2011 | Foundation Center
US National Science Foundation Award Search | 08/26/2011 | http://www.nsf.gov/awardsearch/
US NIH Clinicaltrials.gov | 08/29/2011 | http://www.clinicaltrials.gov/
US NIH Reporter | 08/25/2011 | http://projectreporter.nih.gov/reporter.cfm
US NLM Health Services Research in Progress (HSRProj) | 08/26/2011 | http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm
WHO International Clinical Trials Registry Platform | 08/23/2011 | http://apps.who.int/trialsearch/AdvSearch.aspx
Individual Websites
American Pregnancy Association | 08/25/2011 | http://americanpregnancy.org/
Annals of Internal Medicine | 08/10/2011 | http://www.annals.org/
Wellcome Trust | 08/25/2011 | http://www.wellcome.ac.uk/

## ClinicalTrials.gov Search Results 08/23/2011

Advanced search:

SEARCH TERMS: vaginal OR VBAC OR Dystocia OR augmentation OR membranes

RECRUITMENT: Open Studies

STUDY RESULTS: All Studies

CONDITIONS: (cesarean OR caesarean OR delivery OR outcomes OR birth OR childbirth OR induced OR parturition OR labor OR labour) NOT (preterm OR postpartum)

FIRST RECEIVED: from 01/01/2010 to 08/30/2011

RESULTS = 68

## ICTRP Website Search Results 08/23/2011

Search:

TITLE = labor OR labour OR delivery

CONDITION = labor OR labour OR delivery OR preterm OR term

DATE OF REGISTRATION = 01/01/2010 to 24/08/2011

RESULTS = 64