# Abbreviations

ACOG: American Congress of Obstetricians and Gynecologists
AHRQ: Agency for Healthcare Research and Quality
EHC: Effective Health Care
EPC: Evidence-based Practice Center
ERCD: Elective repeat cesarean delivery
FTP: Failure to progress
ICAN: International Cesarean Awareness Network
NICHD: National Institutes of Child Health & Human Development
TOL: Trial of labor
VBAC: Vaginal birth after cesarean