# Results

Based on the 2011 hypertension CER, the related ACEI/ARB prioritization project in ischemic heart disease, and our discussion with stakeholders, we identified the 25 potential research areas listed in Table 4. Not all areas were considered within the scope of the 2011 CER; these out-of-scope areas are highlighted in italics. Since these areas were out of scope for the original review, it is unclear whether large evidence gaps exist for these areas; however, they were identified and deemed potentially important by the stakeholder panel. With regard to the final stakeholder ranking, 9 out of 10 stakeholders participated and ranked the research priorities. The final ranking is listed below in Table 5 and is divided into a top, middle, and lower tier, based on the overall score.

Table 5 Final ranking of future research needs for ACEIs, ARBs, and DRIs in hypertension

Question | Score
Top Tier
Studies of cardiovascular and cerebrovascular events compared across the three medication classes thereby requiring evaluation of outcomes over several years | 11
Impact of comorbidities (such as ischemic heart disease, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension | 10
Impact of demographic differences (such as age, race, sex) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension | 8
Practical clinical trials or other or other external validity-oriented studies that compare these medications in practice settings that better represent real-world practice. | 8
The impact of ACEI/ARB/DRI on incidence of new cardiovascular or metabolic diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) | 5
The impact of ACEI/ARB/DRI on patient health status including quality of life and functional capacity | 5
Relative medication adherence and persistence with drug therapy across the different classes of drugs. | 5
Middle Tier
The benefit of ACEI/ARB/DRI relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms | 4
The impact of ACEI/ARB/DRI on utilization and cost of therapy | 4
Impact of health risk behaviors such as diet, exercise, smoking, alcohol intake on ACEI/ARB/DRI effectiveness or harms | 3
The impact of ACEI/ARB/DRI on progression of renal insufficiency or development of dialysis dependence | 3
Impact of changing trends in outcome event rates over time on the comparative effectiveness of ACEI, ARBs, and DRIs | 3
Better understanding of provider patterns of prescribing these medications, and of interventions used to support evidence-based decisionmaking about prescribing | 3
Impact of class effect (impact of differences between specific agents within each class) of ACEI/ARB/DRI on their effectiveness or harms | 2
The impact of ACEI/ARB/DRI on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) | 2
Lower Tier
Impact of concurrent medications(such as antiplatelet agents, lipid-lowering medications, diuretics, other antihypertensives) on ACEI/ARB/DRI effectiveness or harms | 1
Methods for synthesis of data across clinical conditions (e.g., CHF, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACEI, ARBs, and DRIs | 1
Methods for individual patient data meta-analysis, to better examine subgroups in the absence of other confounders | 1
Impact of the dose response (impact of medication dose or dosing interval) of ACEI/ARB/DRI on their effectiveness or harms | 0
Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACEI/ARB/DRI effectiveness or harms | 0
The impact of ACEI, ARB, or DRI monotherapy compared to ACEI, ARB, and/or DRI combination therapy in hypertension | 0
The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI combined with aldosterone receptor antagonists | 0
The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI in combination with a diuretic | 0
Evaluation of cancer-related outcomes, which are infrequently reported in the existing literature | 0
Evaluation of the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs | 0

Out-of-scope research topics are highlighted in italics.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; DRI(s) = direct renin inhibitor(s); LV = left ventricular

These final rankings were not significantly changed from the preliminary rankings provided by the stakeholders prior to the second call. Notably, none of the future research areas considered out of scope from the original review appeared in the top tier. Based on the stakeholder-identified top tier, the EPC team discussed potential study designs for each research area—these are listed in Table 6. While the proposed methods to address each area are not intended to be restrictive of potential study designs, this section is intended to discuss the benefits or limitations for each study design for answering these questions.

Table 6 High-priority research areas and possible study designs

Research area | RCT? | Meta-analysis or individual patient data analysis across RCTs? | Meta-analysis of observational studies? | New observational study? | Analysis of existing data? | Model?
What is the comparative effectiveness of these medications on cardiovascular and cerebrovascular events measured over several years? | Maybe: Large number of studies recently completed or ongoing in patients with other comorbidities may make new RCTs unnecessary | Maybe: If recent data is not included in original CER or if it is methodologically valid to combine studies of medication impact across different conditions (such as hypertension, ischemic heart disease, chronic kidney disease) | Maybe: If sufficient number of studies available; adjustment for confounding could be an issue | Maybe: Most direct way to address long-term outcomes; however, resource requirements for longer-term studies are potential limitations | Yes: Most efficient method for evaluating long-term outcomes given the large number of existing studies; appropriate coding for covariates an issue | Maybe: Potential role for helping determine clinically important differences
What is the impact of comorbidities (such as ischemic heart disease, CHF, diabetes, peripheral arterial disease, chronic kidney disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension? | Maybe: May be feasible for common comorbidities; existing or ongoing studies might be sufficient for some | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would require cooperation from the multiple sponsors of RCTs in this area | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would require cooperation from the multiple sponsors; if available, could address less common comorbidities, long-term safety/effectiveness | Maybe: Most direct way to address less common comorbidities; allows for adjustment for confounding; sample size and resources needed for longer follow-up are potential limitations | Yes: Most efficient method for evaluating less common comorbidities over longer time frames; appropriate coding of covariates a potential limitation | No: Except for potential role in defining clinically or economically meaningful differences
What is the impact of demographic differences (such as age, race, sex) on ACEI/ARB/DRIs effectiveness or harms in patients with hypertension? | No: Unlikely to be sufficient power in single RCT to determine differences among subgroups | Maybe: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would likely require cooperation from the multiple sponsors to combine data | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would likely require cooperation from the multiple sponsors to obtain unpublished information | Yes: If new data collection undertaken to address other questions, impact of demographic differences could be estimated in analysis | Yes: Most efficient method for evaluating demographic differences; appropriate coding of other covariates a potential limitation | Maybe: Model could help determine impact of subgroup differences on overall population effectiveness, cost-effectiveness
Do the results differ in practical clinical trials or other or other external validity-oriented studies that compare these medications in practice settings that better represent real-world practice? | Yes: New RCT could however be challenging and could have technical issues with generalizability, existing RCT data may not appropriately represent community setting and participation in study may influence provider practices | Maybe: May be appropriate if sufficient studies available, although not identified in initial review | Maybe: May be appropriate if sufficient studies available; could be difficult to combine observational data from different settings | Yes: Would minimize influence of study protocol on provider practices; sample size and resources needed for longer followup are potential limitations | Maybe: Comparison of existing studies in settings with different incentives and disincentives for evidence-based prescribing | Maybe: Potential role for modeling impact of different rates of outcomes that may be observed outside traditional clinical trial.
What is the impact of ACEI/ARB/DRI on incidence of new cardiovascular or metabolic diagnoses such as diabetes, atrial fibrillation, CHF with or without preserved LV function? | Maybe: Relatively large number of recent or ongoing studies, although not specifically in patients with hypertension; unclear what additional information new RCTs would provide | Yes: Sufficient number of studies, so would be an efficient method for evaluating incidence of new diagnoses; main potential issue is duration of follow-up | Yes: If sufficient observational data available, could efficiently address incidence of new diagnoses over long time frame | Maybe: Most direct way of addressing duration limitations; allows for adjustment for confounding; sample size and resources needed for longer-term follow-up are potential limitations. | Yes: May be most efficient method for evaluating new diagnosis incidence, given resources needed for new study; appropriate coding of covariates a potential limitation | No: Except for potential role in defining clinically or economically meaningful differences
What is the impact of ACEI/ARB/DRI on patient health status including quality of life and functional capacity? | Yes: Given that these outcomes are not frequently reported, incorporation of disease-specific and generic QOL instruments into new trials would be appropriate | Maybe: If additional evidence is available that was not included in the original CER, and if consistent instruments utilized to allow data synthesis | No: Validated QOL instruments rarely reported in observational studies, so likely not appropriate | Yes: Incorporation of QOL instruments into new observational studies would be appropriate and relatively low cost; cross-sectional studies for obtaining population-level utilities reasonable | Maybe: If validated QOL instrument reported in existing studies | Maybe: Potential role for helping determine clinically important differences
Are there important differences in medication adherence and persistence with drug therapy across the different classes of drug? | Maybe: If sufficient data on impact on non-adherence (e.g., difference in outcomes between ITT and adherent populations); major limitation is that RCT subjects may not be generalizable to overall patient population. | Maybe: If additional evidence is available that was not included in the original CER, and if sufficient data reported on impact on non-adherence (e.g., difference in outcomes between ITT and adherent populations); major limitation is that RCT subjects may not be generalizable to overall population | Maybe: If additional evidence available not previously included in the original CER and if data on adherence collected consistently across studies | Yes: Most reliable way to track adherence, but sample size and resources needed for longer follow-up are potential limitations | Maybe: Technical issues with measuring adherence from administrative data | Maybe: Potential role for helping determine clinically important differences

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); DRI(s) = direct renin inhibitor(s); ITT = intention-to-treat; QOL = quality of life; RCT = randomized controlled trial