# Methods

## Overview

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps. Further detail is provided below.

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of future research needs.
2. Create an initial list of evidence gaps based on the CER organized according to the population, interventions, comparators, and outcomes (PICO) framework.9
3. Form a stakeholder group representing appropriate clinician, policymakers, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in December 2010) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on the updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.10

## Analytic Framework

Figure 1 depicts the analytic framework for the CER. Future research areas are linked to the framework using numbers which link the research areas in Table 2, below. The Key Questions were organized within the context of the PICO. In general, the figure illustrates how ACEIs, ARBs, and DRIs may affect: (1) measures of blood pressure control, lipid levels, carbohydrate metabolism/diabetes control, measures of left ventricular mass/function, or measures of kidney disease (creatinine/glomerular filtration rate, proteinuria); and/or (2) clinically significant outcomes, such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially major cardiovascular events [myocardial infarction, stroke], rates of progression to type 2 diabetes, and measures of quality of life). In addition, adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia) may occur at any point after ACEIs, ARBs, and/or DRIs are taken.

Figure 1 Analytic framework

Abbreviations: ACEIs = angiotensin-converting enzyme inhibitors; ARBs = angiotensin receptor blockers; GFR = glomerular filtration rate; LV = left ventricular; MI = myocardial infarction

Figure 1 depicts the analytic framework for the CER. The key questions were organized within the context of the PICO. In general, the figure illustrates how ACEIs, ARBs, and DRIs may affect: (1) measures of blood pressure control, lipid levels, carbohydrate metabolism/diabetes control, measures of left ventricular mass/function, or measures of kidney disease (creatinine/glomerular filtration rate, proteinuria); and/or (2) clinically significant outcomes, such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially major cardiovascular events [myocardial infarction, stroke], rates of progression to type 2 diabetes, and measures of quality of life). In addition, adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia) may occur at any point after ACEIs, ARBs, and/or DRIs are taken. Future research areas are represented in the framework using numbers that link to the research areas listed in Table 2.

Table 2 Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. What is the comparative safety and effectiveness of treatment in subgroups of special importance, such as individuals with essential hypertension and at least one of the following: ischemic heart disease, diabetes mellitus, congestive heart failure, chronic kidney disease, and dyslipidemia?; 2. What is the comparative safety and effectiveness of specific subgroups such as the elderly and ethnic and racial minorities?
Interventions and comparators | 3 Are there differential effects of specific ACEIs, ARBs, or DRIs that are not shared by other agents within their respective medication class?
Outcomes | 4 What is the comparative effectiveness of these medications on cardiovascular and cerebrovascular events measured over several years?; 5 What is the comparative effectiveness of these medications on cancer-related outcomes, which are infrequently reported in the existing literature?; 6 What are the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs?
Implementation gaps | 7 Are there important differences in medication adherence and persistence with drug therapy across the different classes of drug?.; 8 What are the provider patterns of prescribing these medications, and what interventions are used to support evidence-based decisionmaking about prescribing?
Methods for evidence synthesis | 9 What are the best methods for synthesis of data across clinical conditions (e.g. congestive heart failure, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACEIs, ARBs, and DRIs?

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); DRI(s) = direct renin inhibitor(s); PICO = population, interventions, comparators, and outcomes

## Initial List of Research Needs

Results from the 2011 report suggest several evidence gaps for future research. These possibilities are neither exhaustive nor prioritized. The initial list generated by the study authors is provided in Table 2, organized according to the PICO format, with the addition of implementation gaps and methods for evidence synthesis.

## Creation of Stakeholder Group

We selected stakeholders to include researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, healthcare policymakers, and representatives from related consumer and patient advocacy groups (Table 3). This list included generalist and specialist physician perspectives and was solicited through the professional societies listed below. Within each group, we sought to identify an individual who was either familiar with the clinical area and its current uncertainties, or who brought a specific methodological area of expertise to the workgroup.

Table 3 Stakeholder organizations and roles

Organization | Purpose/Role
National Heart Lung and Blood Institute (NHLBI) | The NHLBI is one of the main funders of potential future studies of the comparative safety and effectiveness of ACEIs, ARBs, and DRIs in patients with hypertension; therefore, it was important to include their perspective in the prioritization of future research needs.
American College of Physicians (ACP) | ACP is the largest group representing internal medicine and its subspecialties. Most hypertension is managed by generalists or medicine subspecialists in the office setting and the ACP represents this broad group of stakeholders
Society of General Internal Medicine (SGIM) | Along with the AAFP below, SGIM represents generalist physicians who manage most patients with hypertension. These groups' members are most often the front line providers, managing the majority of patients with hypertension and representing important stakeholder groups.
American Heart Association (AHA) | The AHA funds clinical, outcomes, and health services research in cardiovascular disease and stroke. They are also a leading advocacy group for advancing science and improving the quality of cardiovascular care.
American Society of Hypertension (ASH) | ASH is the subspecialty group representing generalists and specialists with a focus on hypertension care. Their membership is comprised of generalists, cardiologists, and nephrologists and we sought a representative with content expertise in this area for representing future research needs.
American Academy of Family Physicians (AAFP) | Most hypertension medication prescriptions are written by primary care providers. The AAFP represented family physicians that were not otherwise included in any of the internal medicine stakeholder groups.
Payer | We sought a representative from a private payer and a representative from Blue Cross/Blue Shield of North Carolina participated. Although payers may not fund future research projects, we sought their opinion on the information needed to change their coverage decisions.
Patient Advocate | We identified a patient advocate to represent the research priorities and issues from the patient's perspective.
Centers for Medicare & Medicaid (CMS) | We sought a representative from CMS. Although CMS may not fund future research projects, like private insurers, they are important decisionmakers in prescription coverage.

Abbreviations: AAFP = American Academy of Family Physicians; ACEI(s) = angiotensin-converting enzyme inhibitor(s); ACP = American College of Physicians; AHA = American Heart Association; ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); ASH = American Society of Hypertension; CMS = Centers for Medicare & Medicaid Services; DRI(s) = direct renin inhibitor(s); NHLBI = National Heart Lung and Blood Institute; SGIM = Society of General Internal Medicine

We were able to recruit a representative from each of these nine groups. In addition, we identified a clinical pharmacist with expertise in ACEIs, ARBs, and experience in comparative effectiveness research. A total of 10 stakeholders were included in our final panel.

Stakeholder input was solicited and received through web-based survey techniques, email, and group discussions via teleconference. Group discussions were moderated by the EPC investigators to avoid domination of the discussion by any particular group and to ensure that all participants had an equal opportunity to ask questions and express their views. The AHRQ Task Order Officer was a participant in all group teleconferences and was included on all electronic communication with the stakeholder group.

Each potential stakeholder completed a statement of disclosure, was screened for apparent conflicts of interest, and approved by AHRQ prior to the first stakeholder call. Efforts were made to assemble a balanced group of individuals representing a wide range of perspectives.

## Expansion of Research Gaps

We used the research priorities identified in the CER and also examined a complementary list of priorities taken from a related AHRQ-sponsored project entitled, “Future Research Needs for Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease.”11 Based on input from the stakeholder workgroup during the first call, we ultimately expanded the list of research priorities as shown in Table 4.

Table 4 Potential future research needs based on the CER and stakeholder input

PICO Element | Potential Future Research Need^*^
Population | 1. Impact of comorbidities (such as ischemic heart disease, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension; 2. Impact of demographic differences (such as age, race, sex) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension; 3. Impact of genetic differences (such as ACEI or angiotensin II receptor gene polymorphisms) on ACEI/ARB/DRI effectiveness or harms.; 4. Impact of health risk behaviors such as diet, exercise, smoking, alcohol intake on ACEI/ARB/DRI effectiveness or harms
Intervention and comparator | 5 Impact of the dose response (impact of medication dose or dosing interval) of ACEI/ARB/DRI on their effectiveness or harms; 6 Differential impact of specific agents or subclasses (based on tissue specificity, chemical properties, or pharmacokinetics) within each medication class on ACEI/ARB/DRI effectiveness or harms; 7 The benefit of ACEI/ARB/DRI relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms; 8 Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, diuretics, other antihypertensives) on ACEI/ARB/DRI effectiveness or harms; 9 The impact of ACEI/ARB/DRI monotherapy compared to ACEI, ARB, and/or DRI combination therapy in essential hypertension; 10 The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI combined with aldosterone receptor antagonists; 11 The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI in combination with a diuretic
Outcome | 12 Studies of cardiovascular and cerebrovascular events compared across the three medication classes thereby requiring evaluation of outcomes over several years; 13 Evaluation of cancer-related outcomes, which are infrequently reported in the existing literature.; 14 Evaluation of the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs.; 15 The impact of ACEI/ARB/DRI on incidence of new cardiovascular or metabolic diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function); 16 The impact of ACEI/ARB/DRI on patient health status including quality of life and functional capacity; 17 The impact of ACEI/ARB/DRI on utilization and cost of therapy; 18 The impact of ACEI/ARB/DRI on progression of renal insufficiency or development of dialysis dependence; 19 The impact of ACEI/ARB/DRI on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia); 20 Impact of changing trends in outcome event rates over time on the comparative effectiveness of ACEI, ARBs, and DRIs.
Implementation gaps | 21 Relative medication adherence and persistence with drug therapy across the different classes of drugs.; 22 Studies of the impact of health system financing, delivery, and/or organization interventions on evidence based medication prescribing and patient adherence.; 23 Practical clinical trials or other or other external-validity-oriented studies that compare these medications in practice settings that better represent real-world practice.
Methods for evidence synthesis | 24 Methods for synthesis of data across clinical conditions (e.g., congestive heart failure, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACEIs, ARBs, and DRIs.; 25 Methods for individual patient data meta-analysis, to better examine subgroups in the absence of other confounders

* Out-of-scope research topics are in italics.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; DRI(s) = direct renin inhibitor(s); LV = left ventricular); PICO = population, interventions, comparators, and outcomes

While most of these research areas were within the scope of the initial review, several raised by the stakeholder group were outside the scope of this review. These areas may represent important gaps in the knowledge base; however, we are less confident about the current state of the evidence since they were not included in the original report. These “out-of-scope” topics were included in our list, but were specifically noted so that the stakeholders were aware that these areas had not undergone the same level of systematic review and we, therefore, could not provide the same level of detail on the state of current evidence.

We have organized these gaps according to the PICO format and listed them in the table below. The areas determined to be out of scope from the original review are italicized in Table 4.

## Review of the Current Literature

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These searches included the following:

1. A search of ClinicalTrials.gov for ongoing studies. This search included the key words “ACEI OR ACE-I OR ARB OR DRI OR Angiotensin OR Renin” and was limited to open studies in adults received from 12/7/2007 to 12/7/2011.
2. An update of the MEDLINE^®^ (via Ovid) search used in the original CER entitled,
3. “Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACE-Is) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension,”6 to identify relevant RCT literature published since the last search date (12/23/10).
4. A search of PubMed^®^ for relevant systematic reviews and meta-analyses published from 2008 to the present, which might address the out of scope evidence gaps.

The exact search strategies used are provided in Appendix A.

Search results were reviewed for applicability to the identified research gaps listed in Table 4. We included articles from each search if they met the following criteria: (1) included patients with hypertension; (2) reported original data or combined original data in a systematic review or decision analysis; (3) included a comparison between an ACEI, ARB, or DRI and either an alternative medication, another ACEI, ARB, DRI, or placebo; and (4) included outcomes that could be categorized according to our identified list of research priorities. The goal for this literature search was to provide the stakeholders an idea of which research areas had recent or ongoing literature to address these gaps. Since we did not intend to synthesize this data with the existing report, these articles did not undergo full article abstraction or reconciliation of differences between article reviewers.

The search of each database yielded the following list of articles:

- Clinicaltrials.gov:
  - 86 active protocols submitted since 12/2007
  - 11 included as potentially relevant based on screening
  - All RCTs
  - Sample size: 60 patients to 720 patients
- Updated MEDLINE/PubMed:
  - 167 articles found on original search
  - 31 included as potentially relevant based on abstract screening
  - Duration of followup range: 12 weeks to 30 weeks
- PubMed search of systematic reviews on out of scope topics:
  - 356 articles identified
  - 32 included and linked to an out of scope research gap

Based on these searches, we created a list of articles and clinical trials pertaining to the 25 identified evidence gaps. This document was provided to the stakeholders prior to their final prioritization and is reproduced in Appendix B.

## Research Prioritization

### Process Used

The stakeholders were provided the AHRQ Effective Health Care Program Selection Criteria and instructed to use these criteria as the basis for their decisions regarding research prioritization:

Appropriateness
- Represents a health care drug, intervention, device, technology or health care system/setting available (or soon to be available) in the United States
- Relevant to 1013 enrollees (Medicare, Medicaid, Children's Health Insurance Program [CHIP], other Federal health care programs)
- Represents one of the priority conditions designated by the U.S. Department of Health and Human Services (HHS)

Importance
- Represents a significant disease burden, large proportion or priority population
- Is of high public interest; affects health care decisionmaking, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
- Was nominated/strongly supported by one or more stakeholder groups
- Represents important uncertainty for decisionmakers
- Incorporates issues around both clinical benefits and potential clinical harms
- Represents important variation in clinical care, or controversy in what constitutes appropriate clinical care
- Represent high costs to consumers, patients, health care systems or payers; due to common use, high unit costs, or high associated costs

Desirability of new research/duplication
- Would not be redundant (i.e., the proposed topic is not already covered by available or soon-to-be available high-quality systematic reviews by AHRQ or others)

Feasibility
- Effectively uses existing research and knowledge by considering adequacy of research for conducting a systematic review and newly available evidence

Potential impact
- Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

Participants in our stakeholder group participated in two conference calls, each of which was followed by an online prioritization exercise. The first call (October 2011) was used to introduce the stakeholder group to the project's objective and to describe the key clinical questions, the original CER report and its findings, and the proposed methods for the prioritization process. During this meeting, the identified research priorities were introduced to the stakeholders, and the group was invited to share feedback regarding additional research priorities. Following this conference call (December 2011), the stakeholders were invited to perform an initial online ranking of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 9 votes, which could be allocated to any of the 25 research priorities, with a maximum of 3 votes per item.

Stakeholders then participated in a second conference call (December 2011), during which the Duke EPC team shared the search results for relevant ongoing and recently published studies, as well as the stakeholders' initial ranking of research priorities results. During this conference call, the majority of the time was dedicated to discussing prioritization. Following this second call, a final online ranking exercise was distributed to the stakeholder group. This exercise utilized the same prioritization method as the first ranking exercise, and produced the final ranked list of research priorities. Research needs were ranked into tiers; only those in the top tier moved on to the final stage of study design development.

### Research Question Development and Research Design Considerations

For the top tier future research needs, we considered advantages and disadvantages of various potential study designs. We adapted a conceptual framework for recommending study designs based on our prior future research needs report on ACEI and ARBs in ischemic heart disease.11 Our overall approach to recommending study designs for addressing specific evidence gaps was to emphasize the study design with the least risk of bias, but the greatest likelihood of completion. For areas outside of the original CER scope, we suggested specific study designs that may be appropriate, while remaining cognizant that without a comprehensive systematic review, one cannot determine with certainty the degree to which those evidence gaps have already been addressed. A thorough systematic review may be the most appropriate initial step before further original research is undertaken for the priorities out of scope from the CER. The figure depicting this framework and a discussion of different designs is included in Appendix C.