# Stakeholders

Javed Butler, M.D., M.P.H.

Deputy Chief Science Advisor, American Heart Association

Professor of Medicine

Emory University

Atlanta, GA

Laurence J. Clark, M.D.

Contractor Medical Director

Highmark Medicare Services, Inc.

Washington, DC

Lee Albert Green, M.D., M.P.H.

Professor of Family Medicine

University of Michigan Medical School

Ann Arbor, MI

Patrice Desvigne-Nickens, M.D.

Program Director in Heart Failure and Arrhythmia Branch

Division of Cardiovascular Disease

National Heart Lung and Blood Institute

Bethesda, MD

Amir Qaseem, M.D., Ph.D., M.H.A.

Director, Department of Clinical Policy

Medical Education Division

American College of Physicians

Philadelphia, PA

Allison Rosen, M.D., M.P.H., Sc.D.

Associate Professor, Department of Quantitative Health Sciences, Department of Medicine, Graduate School of Biomedical Sciences

University of Massachusetts Medical School

Worcester, MA

Barbara Warren, Psy.D.

Distinguished Lecturer and Director, Center for LGBT Social Science and Public Policy

Roosevelt House Public Policy Institute

Hunter College

New York, NY

C. Michael White, Pharm.D.

Department Head of Pharmacy Practice

School of Pharmacy

University of Connecticut

Storrs, CT;

Director, University of Connecticut/Hartford Hospital Evidence-based Practice Center

Hartford, CT

William B. White, M.D.

President-Elect, American Society of Hypertension

Chief, Division of Hypertension and Clinical Pharmacology

Cardiology Center

University of Connecticut Health Center

Farmington, CT

Lawrence R. Wu, M.D.

Regional Medical Director and Lead Medical Director for Employee Health, Blue Cross Blue Shield of North Carolina

Associate Consulting Professor, Duke University School of Medicine

Durham, NC