# Executive Summary

## Background

Almost 75 million American adults have hypertension. Advances in antihypertensive therapy have dramatically reduced cardiovascular, cerebrovascular, and renal events.1-3 Among the effective pharmacotherapies are inhibitors of the renin-angiotensin-aldosterone system (RAS). In 2007, the Agency for Healthcare Research and Quality (AHRQ) sponsored a comparative effectiveness review (CER) of the two most common renin system inhibitors, angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin receptor blockers (ARBs), to answer the following three Key Questions for adults with essential hypertension: do ACEIs and ARBs differ in their (1) blood pressure control, cardiovascular events, quality of life, and other outcomes; (2) safety, tolerability, persistence with therapy, or treatment adherence; and (3) effects within important subgroups of patients?4,5 This 2007 CER was updated in 2011 to incorporate the significant additional direct comparison research published in the interval and to include direct renin inhibitors (DRIs), which are the newest class of RAS inhibitors.6,7

The results of the updated CER included 97 studies (36 new since 2007) directly comparing ACEIs versus ARBs and 3 studies directly comparing DRIs to ACEIs or ARBs. The strength of evidence remained high for equivalence between ACEIs and ARBs for blood pressure lowering, and for superiority of ARBs over ACEIs for short-term adverse events (primarily cough). The new evidence did not strengthen the conclusions regarding long-term cardiovascular outcomes, quality of life, progression of renal disease, medication adherence or persistence, rates of angioedema, or differences in key patient subgroups; the strength of evidence for these outcomes remained low to moderate (Table A). Evidence on the comparative effectiveness of DRIs versus either ACEIs or ARBs was limited to 3 studies with 2,049 patients and did not allow definitive conclusions on any of the included outcomes. Few studies involved a representative patient sample treated in a typical clinical setting over a long duration; treatment protocols had marked heterogeneity; and significant amounts of data about important outcomes and patient subgroups were missing.

Table A Initial list of evidence gaps

PICO Element | Evidence Gaps
Population | 1. What are the comparative safety and effectiveness of treatment in subgroups of special importance, such as individuals with essential hypertension and at least one of the following: ischemic heart disease, diabetes mellitus, congestive heart failure, chronic kidney disease, and dyslipidemia?; 2. What are the comparative safety and effectiveness in specific subgroups such as the elderly and ethnic and racial minorities?
Interventions and comparators | 3 Are there differential effects of specific ACEIs, ARBs, or DRIs that are not shared by other agents within their respective medication class?
Outcomes | 4 What is the comparative effectiveness of these medications on cardiovascular and cerebrovascular events measured over several years?; 5 What is the comparative effectiveness of these medications on cancer-related outcomes, which are infrequently reported in the existing literature?; 6 What are the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs?
Implementation gaps | 7 Are there important differences in medication adherence and persistence with drug therapy across the different classes of drug?; 8 What are the provider patterns of prescribing these medications, and what interventions are used to support evidence-based decisionmaking about prescribing?
Methods for evidence synthesis | 9 What are the best methods for synthesis of data across clinical conditions (e.g. congestive heart failure, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACEIs, ARBs, and DRIs?

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); DRI(s) = direct renin inhibitor(s); PICO = population, interventions, comparators, and outcomes.

Given the clinical and economic importance of these medications, the ongoing investment in research, and the remaining areas of uncertainty, we sought to create a prioritized research agenda representing the interests of diverse stakeholders in order to address the remaining areas of uncertainty.

## Analytic Framework

We organized the research areas into an analytic framework depicted in Figure A. The Key Questions are organized within the context of the population, interventions, comparators of interest, and outcomes (PICO) in Table A and displayed accordingly in the analytic framework.

Figure A Analytic framework

Abbreviations: ACEIs = angiotensin-converting enzyme inhibitors; ARBs = angiotensin receptor blockers; GFR = glomerular filtration rate; KQ = Key Question; LV = left ventricular; MI = myocardial infarction.

Figure A depicts the analytic framework for the CER. The key questions were organized within the context of the PICO. In general, the figure illustrates how ACEIs, ARBs, and DRIs may affect: (1) measures of blood pressure control, lipid levels, carbohydrate metabolism/diabetes control, measures of left ventricular mass/function, or measures of kidney disease (creatinine/glomerular filtration rate, proteinuria); and/or (2) clinically significant outcomes, such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially major cardiovascular events [myocardial infarction, stroke], rates of progression to type 2 diabetes, and measures of quality of life). In addition, adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia) may occur at any point after ACEIs, ARBs, and/or DRIs are taken. Future research areas are represented in the framework using numbers that link to the research areas listed in Table 2.

## Methods

Our approach to identifying evidence gaps, prioritizing future research, and developing recommendations for stakeholders is outlined in the following steps:

1. Develop an analytic framework from the original CER in order to understand the clinical and policy context of the review and its initial list of future research needs.
2. Create an initial list of evidence gaps organized according to the PICO (population, interventions, comparators, and outcomes) framework.8
3. Form a stakeholder workgroup representing appropriate professional societies, policymakers, and patient perspectives.
4. Expand the list of evidence gaps based on stakeholder input.
5. Perform an updated review of published literature since the last CER (search last updated in December 2010) and a horizon scan for recently published and ongoing studies that may address the evidence gaps, but which are not included in the current CER.
6. Solicit stakeholder prioritization of the identified research gaps based on updated literature review.
7. Determine the most appropriate study designs for the highest priority research areas.9

Stakeholders were selected to include researchers involved in some of the primary randomized controlled trials (RCTs) included in the CER, other clinical experts and researchers in the content area, representatives from Federal and nongovernmental funding agencies, representatives from relevant professional societies, health care policymakers, and representatives from related consumer and patient advocacy groups.

We used the research priorities identified in the CER and also examined a complementary list of priorities taken from a related AHRQ-sponsored project, Future Research Needs for Angiotensin Converting Enzyme (ACE) Inhibitors or Angiotensin II Receptor Blockers (ARBs) added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease.10 Based on input from the stakeholder workgroup during the first call, we ultimately expanded the list of research priorities from a list of 9 to a total of 25.

We performed three database searches to identify ongoing and recently published studies relevant to the identified evidence gaps. These included a search of ClinicalTrials.gov, an update of the MEDLINE^®^ search used in the original CER, and a search of PubMed^®^ for relevant systematic reviews that may address the evidence gaps considered out of scope in the original review. Based on these searches, a document was created listing all included articles and clinical trials that might pertain to the 25 listed evidence gaps.

The stakeholders were provided with the AHRQ Effective Health Care Program Selection Criteria and instructed to use these criteria as the basis for their decisions regarding research prioritization. The stakeholders performed an online ranking of the identified research priorities (including the additional priorities identified by the stakeholder team). This ranking utilized a forced-ranking prioritization method, whereby participants were given 9 votes to allocate to any of the 25 research priorities, with a maximum of 3 votes per item.

For the top tier future research needs, we considered potential study designs and their advantages and disadvantages.9 While these proposed methods to address each area are not intended to be restrictive of potential study designs, we comment on each design's potential benefits or limitations for answering these questions.

## Results

Based on the 2011 hypertension CER6, the related ACEI/ARB prioritization project in ischemic heart disease, and our discussion with stakeholders, we identified the 25 potential research areas.10 The stakeholder voting identified seven highest priority areas of future research, and these results were consistent over two separate prioritization exercises. The research priorities are shown in Table B.

Table B Final ranking of future research needs for ACEIs, ARBs, and DRIs in hypertension

Question | Score
Top Tier
Studies of cardiovascular and cerebrovascular events compared across the three medication classes, thereby requiring evaluation of outcomes over several years. | 11
Impact of comorbidities (such as ischemic heart disease, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization, single- vs. multi-vessel coronary artery disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension. | 10
Impact of demographic differences (such as age, race, sex) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension. | 8
Practical clinical trials or other or other external validity–oriented studies that compare these medications in practice settings that better represent real-world practice. | 8
The impact of ACEI/ARB/DRI on incidence of new cardiovascular or metabolic diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function). | 5
The impact of ACEI/ARB/DRI on patient health status including quality of life and functional capacity. | 5
Relative medication adherence and persistence with drug therapy across the different classes of drugs. | 5
Middle Tier
The benefit of ACEI/ARB/DRI relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms. * | 4
The impact of ACEI/ARB/DRI on utilization and cost of therapy. | 4
Impact of health risk behaviors such as diet, exercise, smoking, alcohol intake on ACEI/ARB/DRI effectiveness or harms . | 3
The impact of ACEI/ARB/DRI on progression of renal insufficiency or development of dialysis dependence. | 3
Impact of changing trends in outcome event rates over time on the comparative effectiveness of ACEI, ARBs, and DRIs. | 3
Better understanding of provider patterns of prescribing these medications, and of interventions used to support evidence-based decisionmaking about prescribing. | 3
Impact of class effect (impact of differences between specific agents within each class) of ACEI/ARB/DRI on their effectiveness or harms. | 2
The impact of ACEI/ARB/DRI on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia). | 2
Lower Tier
Impact of concurrent medications (such as antiplatelet agents, lipid-lowering medications, diuretics, other antihypertensives) on ACEI/ARB/DRI effectiveness or harms. | 1
Methods for synthesis of data across clinical conditions (e.g., CHF, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACEI, ARBs, and DRIs. | 1
Methods for individual patient data meta-analysis, to better examine subgroups in the absence of other confounders. | 1
Impact of the dose response (impact of medication dose or dosing interval) of ACEI/ARB/DRI on their effectiveness or harms. | 0
Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACEI/ARB/DRI effectiveness or harms‥ | 0
The impact of ACEI, ARB, or DRI monotherapy compared to ACEI, ARB, and/or DRI combination therapy in hypertension. | 0
The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI combined with aldosterone receptor antagonists. | 0
The impact of ACEI/ARB/DRI alone compared to ACEI/ARB/DRI in combination with a diuretic. | 0
Evaluation of cancer-related outcomes, which are infrequently reported in the existing literature. | 0
Evaluation of the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs. | 0

* Out-of-scope research topics are highlighted in italics.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CHF = congestive heart failure; DRI(s) = direct renin inhibitor(s); LV = left ventricular

## Discussion

The recommendations for future research prioritization of ACEIs, ARBs, and DRIs in this report represents the perspectives of a broad range of stakeholders, including general physicians, physician specialists, researchers, policymakers, and patients. The top tier of seven research priorities remained stable between our first and second prioritization exercise. These areas represent three primary foci: (1) heterogeneity in treatment response (i.e., impact of comorbidities and demographic differences); (2) long-term clinical outcomes (i.e., cardiovascular and cerebrovascular events, incident diabetes or cardiovascular diagnoses, quality of life); and (3) implementation and generalizability (i.e., practical research designs and medication adherence/persistence).

The stakeholder group included several topics that were out of the scope of the original review. The expansion of topics promotes consideration of new areas of research that have not been adequately explored. Nevertheless, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that the existing literature may already adequately address these areas. Among our highest rated research priorities, there were no topics clearly out of the scope of the original review, but formal means of guiding the prioritization of topics both in and out of scope would be helpful for future projects.

## Conclusions

A workgroup of 10 stakeholders identified the following seven research areas as the highest priority for future research for the comparative effectiveness of ACEIs, ARBs, or DRIs in patients with hypertension.

1. What is the comparative effectiveness of these medications on cardiovascular and cerebrovascular events measured over several years?
  a. Recommended study design: if able to combine with chronic conditions other than hypertension, then a systematic review with broader inclusion criteria could provide additional information not included in the CER, which was restricted to patients with hypertension. If not, then large long-term clinical trial or observational study would be preferable.
2. What is the impact of comorbidities (such as ischemic heart disease, CHF, diabetes, peripheral arterial disease, or chronic kidney disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension?
  a. Recommended study design: if patient-level data are available from relevant trials, then a patient-level meta-analysis may be the most efficient approach.
3. What is the impact of demographic differences (such as age, race, or sex) on the effectiveness or harms of ACEI/ARB/DRIs in patients with hypertension?
  a. Recommended study design: if patient-level data are available from relevant trials, then a patient-level meta-analysis is most appropriate.
4. Do the results differ in practical clinical trials or other external validity-oriented studies that compare these medications in practice settings that better represent real-world practice?
  a. Recommended study designs: either a large clinical trial with broader inclusion criteria to maximize generalizability, or an observational study of patients in typical community practice.
5. What is the impact of ACEI/ARB/DRIs on incidence of new cardiovascular or metabolic diagnoses such as diabetes, atrial fibrillation, or CHF with or without preserved LV function?
  a. Recommended study design: if patients can be combined across clinical conditions (i.e., not exclusively hypertension), then a systematic review of existing studies is most appropriate.
6. What is the impact of ACEI/ARB/DRIs on patient health status, including quality of life and functional capacity?
  a. Recommended study design: randomized controlled trials (RCTs) with the inclusion of validated quality of life measures as an outcome.
7. Are there important differences in medication adherence and persistence with drug therapy across the different classes of drug?
  a. Recommended study design: new observational studies with a focus on the longitudinal measurement of adherence and persistence

## Glossary

ACEI: angiotensin-converting enzyme inhibitor
AHRQ: Agency for Healthcare Research and Quality
ARB: angiotensin receptor blocker
CER: comparative effectiveness review
DRI: direct renin inhibitors
EPC: Evidence-based Practice Center
PICO: population, interventions, comparators, and outcomes
RAS: renin-angiotensin system
RCT: randomized controlled trial

## References

1 Collins R, Peto R, MacMahon S, et al. Blood pressure, stroke, and coronary heart disease. Part 2, Short-term reductions in blood pressure: overview of randomised drug trials in their epidemiological context. Lancet. 1990;335(8693):827-38. [pmid: 1969567].
2 Lewington S, Clarke R, Qizilbash N, et al. Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. [Erratum appears in Lancet. 2003 Mar 22;361(9362):1060]. Lancet. 2002;360(9349):1903-13. [pmid: 12493255].
3 Casas JP, Chua W, Loukogeorgakis S, et al. Effect of inhibitors of the renin-angiotensin system and other antihypertensive drugs on renal outcomes: systematic review and meta-analysis. Lancet. 2005;366(9502):2026-33. [pmid: 16338452].
4 Matchar DB, McCrory DC, Orlando LA, et al. Comparative Effectiveneness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension. Comparative Effectiveness Review No. 10. (Prepared by Duke Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. March 14, 2010.
5 Matchar DB, McCrory DC, Orlando LA, et al. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers for treating essential hypertension. Ann Intern Med. 2008;148(1):16-29. [pmid: 17984484].
6 Sanders GD, Coeytaux R, Dolor RJ, et al. Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), and Direct Renin Inhibitors for Treating Essential Hypertension: An Update. Comparative Effectiveness Review No. 34. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025.) AHRQ Publication No. 11-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. August 8, 2011.
7 Powers BJ, Coeytaux RR, Dolor RJ, et al. Updated report on comparative effectiveness of ACE inhibitors, ARBs, and direct renin inhibitors for patients with essential hypertension: much more data, little new information. J Gen Intern Med. 2011. Epub ahead of print, 6 December 2011. [pmid: 22147122].
8 Robinson KA, Saldanha IJ, McKoy NA. Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol. 2011;64(12):1325-30. [pmid: 21937195].
9 Anonymous. Framework for Considering Study Designs for Future Research Needs (FRN). DRAFT Methods Research on Future Research Needs Report. Rockville, MD. Agency for Healthcare Research and Quality. September. 2011. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=774. February 3, 2012.
10 Sanders GD, Powers B, Crowley M, et al. Future Research Needs for Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease. Future Research Needs Paper No. 8. (Prepared by Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I) AHRQ Publication No. 11-EHC006-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2010. Available at: http://www.effectivehealthcare.ahrq.gov/reports/final.cfm. January 19, 2012.