# Discussion

The 2011 update of the 2007 CER of ACEIs, ARBs, and DRIs in essential hypertension clearly demonstrated that this is an active area of research with 59 percent more studies than the 2007 report. However, data from these new studies have not significantly changed the conclusions or the strength of evidence from the original report. These studies reported additional data on blood pressure lowering, adverse events, and cough, but with little added precision for our estimates of effect which were known with a high level of certainty. Conversely, the new evidence reported did not significantly add to our understanding of long-term outcomes, quality of life, renal outcomes, medication adherence, or differences in key patient subgroups. This emphasized that new studies are not appropriately targeting the remaining areas of uncertainty7 and emphasizes the need to clearly define future research priorities. The recommendations for future research on ACEI, ARBs, and DRIs found in this report represent a broad range of stakeholder perspectives including those of general physicians, physician specialists, researchers, policymakers, and patients. The prioritized areas represent three primary foci: (1) heterogeneity in treatment response (i.e., impact of comorbidities and demographic differences); (2) long-term clinical outcomes (i.e., cardiovascular and cerebrovascular events, incident diabetes or cardiovascular diagnoses, quality of life); and (3) implementation and generalizability (i.e., practical research designs and medication adherence/persistence).

Notably, these three areas are very similar to the highest future research priorities identified during a recent Future Research Needs project on ACEI and ARBs in ischemic heart disease. Six of the top seven future research priorities in the hypertension report are also represented in the top seven future research priorities in the ischemic heart disease report.11 The similarities between the research priorities for these medications in ischemic heart disease and hypertension may be explained in part by the overlap of two stakeholders who participated in the ischemic heart disease and hypertension prioritization projects. Nevertheless, given the complete group of 10 stakeholders within the hypertension project and 9 within the ischemic heart disease project, these 2 stakeholders who participated in both projects constituted a minority and were, therefore, not excessively influential in the discussion. This commonality has important implications for how CERs of common comparators are designed. These pharmacotherapies have been compared in large studies and in systematic reviews for multiple related conditions such as congestive heart failure, ischemic heart disease, and chronic kidney disease.8,12,13 These systematic reviews, like the one used for the basis of our report, have limited inclusion to studies conducted in patients with the target condition; however, they examine an overlapping set of efficacy and safety outcomes. Combining studies which report identical outcomes in different target populations may potentially yield important new information that could address the identified research gaps. This approach may be particularly useful for infrequent outcomes such as vascular events, new diagnoses, or mortality where greater statistical power is needed.14

Given the limited time the stakeholders have to review the existing evidence, it is also possible that their prioritization represent their general research priorities, rather than the state of evidence for this specific topic. The tendency to view a scientific problem through the prism of one's preconceived ideas or personal research agenda is well known. As AHRQ prepares further prioritization reports, it would be interesting to examine recurrent themes that arise in the top tier of research priorities.

The stakeholder group included several topics that were out-of-scope for the original review. The expansion of topics promotes consideration of new areas of research that have not been adequately explored; however, the original CER did not comment on the state of current research in these out-of-scope areas, and they should only be promoted with the caveat that existing literature may already adequately address these areas. We identified recent systematic reviews on these out-of-scope topics, but we cannot summarize the state of evidence with the same rigor as in-scope topics included in the original CER. Among our highest rated research priorities, there were no topics clearly out of the scope of the original review, but a formal means of guiding the prioritization of in- and out-of-scope topics would be helpful for future projects.