# Background

Hypertension is the most common reason older adults visit the doctor and advances in antihypertensive therapy have dramatically reduced the associated cardiovascular, cerebrovascular, and renal events.1-3 Inhibitors of the renin-angiotensin system (RAS) are the most frequently used medications for blood pressure control and are highly efficacious for reducing hypertension-related outcomes. In 2007, a comparative effectiveness review (CER) sponsored by the Agency for Healthcare Research and Quality (AHRQ) evaluated the long-term benefits and harms of the two most common classes of RAS inhibitors for treating essential hypertension in adults: angiotensin-converting enzyme inhibitors (ACEIs) and angiotensin II receptor blockers/antagonists (ARBs).4,5 This 2007 CER was updated in 2011 to incorporate the significant additional direct comparison research published in the interval, and to include the direct renin inhibitors (DRIs), which are the newest class of RAS inhibitors.6,7 The 2011 CER addressed the three following Key Questions:

Key Question 1 For adult patients with essential hypertension, how do ACEIs, ARBs, and DRIs differ in blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes?
Key Question 2 For adult patients with essential hypertension, how do ACEIs, ARBs, and DRIs differ in safety, adverse events, tolerability, persistence with drug therapy, and treatment adherence?
Key Question 3 Are there subgroups of patients—based on demographic and other characteristics (i.e., age, race, ethnicity, sex, comorbidities, concurrent use of other medications)—for whom ACEIs, ARBs, or DRIs are more effective, are associated with fewer adverse events, or are better tolerated?

The results of the CER included 97 studies (36 new since 2007) directly comparing ACEIs versus ARBs and 3 studies directly comparing DRIs to ACEIs or ARBs. The strength of evidence remained high for equivalence between ACEIs and ARBs for blood pressure lowering, and for superiority of ARBs over ACEIs for short-term adverse events (primarily cough). The new evidence did not strengthen the conclusions regarding long-term cardiovascular outcomes, quality of life, progression of renal disease, medication adherence or persistence, rates of angioedema, or differences in key patient subgroups; the strength of evidence for these outcomes remained low to moderate (Table 1). Evidence on the comparative effectiveness of DRIs versus either ACEIs or ARBs was limited to 3 studies with 2,049 patients and did not allow definitive conclusions on any of the included outcomes. Few studies involved a representative patient sample treated in a typical clinical setting over a long duration; treatment protocols had marked heterogeneity; and significant amounts of data about important outcomes and patient subgroups were missing.

Table 1 Summary of evidence on comparative long-term benefits and harms of ACEIs, ARBs, and DRIs in patients with essential hypertension

Key Question | Strength of Evidence, Updated Report | Conclusions
1. Key Question 1. For adult patients with essential hypertension, how do ACE inhibitors, ARBs, and direct renin inhibitors differ in the following health outcomes: a. Blood pressure control? | High (ACE inhibitor vs. ARB); | ACE inhibitors and ARBs appear to have similar long-term effects on blood pressure among individuals with essential hypertension. This conclusion is based on evidence from 77 studies (70 RCTs, 5 nonrandomized controlled clinical trials, 1 retrospective cohort study, and 1 case-control study) in which 26,170 patients receiving an ACE inhibitor or an ARB were followed for periods from 12 weeks to 5 years (median 24 weeks). Blood pressure outcomes were confounded by additional treatments and varying dose escalation protocols.
1. Key Question 1. For adult patients with essential hypertension, how do ACE inhibitors, ARBs, and direct renin inhibitors differ in the following health outcomes: a. Blood pressure control? | Low (DRI vs. ACE inhibitor or ARB) | Evidence concerning the effect of DRIs on blood pressure is very limited and currently based on only three studies. These studies found the DRI to have a greater reduction in blood pressure compared to the ACE inhibitor ramipril (two studies) and no significant difference compared to the ARB losartan (one study).
b. Mortality and major cardiovascular events? | Low (ACE inhibitor vs. ARB); | Due to low numbers of deaths or major cardiovascular events reported, it was difficult to discern any differential effect of ACE inhibitors versus ARBs versus DRIs with any certainty for these critical outcomes. In 21 studies that reported mortality, MI, or clinical stroke as outcomes among 38,589 subjects, there were 38 deaths and 13 strokes reported. This may reflect low event rates among otherwise healthy patients and relatively few studies with extended followup.
b. Mortality and major cardiovascular events? | Insufficient (DRI vs. ACE inhibitor or ARB) | Only 3 of these 21 studies (including 1 death) evaluated DRIs versus ACE inhibitors or ARBs, and therefore the evidence to discern any differential effects between these drug classes on mortality and major cardiovascular events was insufficient.
c. Quality of life? | Low (ACE inhibitor vs. ARB); | No differences were found between ACE inhibitors and ARBs in measures of general quality of life; this is based on four studies, two of which did not provide quantitative data.
c. Quality of life? | Insufficient (DRI vs. ACE inhibitor or ARB) | No study evaluated the comparative effectiveness of DRIs for quality-of-life outcomes.
d. Rate of use of a single antihypertensive medication? | High (ACE inhibitor vs. ARB); | There was no statistically evident difference in the rate of treatment success based on use of a single antihypertensive for ARBs compared to ACE inhibitors. The trend toward less frequent addition of a second agent to an ARB was heavily influenced by retrospective cohort studies, where medication discontinuation rates were higher in ACE inhibitor-treated patients, and by RCTs with very loosely defined protocols for medication titration and switching.
d. Rate of use of a single antihypertensive medication? | Insufficient (DRI vs. ACE inhibitor or ARB) | There were no relevant studies evaluating DRIs.
e. Risk factor reduction and other intermediate outcomes? | Moderate (lipid levels, markers of carbohydrate metabolism/diabetes control, progression of renal disease) (ACE inhibitor vs. ARB); | There were no consistent differential effects of ACE inhibitors, ARBs, on several potentially important clinical outcomes, including lipid levels and markers of carbohydrate metabolism/diabetes control. There appears to be a small difference in change in renal function between ACE inhibitors and ARBs (favoring ACE inhibitors), but this difference is both small and most likely not clinically meaningful or significant. Relatively few studies assessed these outcomes over the long term.
e. Risk factor reduction and other intermediate outcomes? | Insufficient (DRI vs. ACE inhibitor or ARB) | There were no studies that evaluated these outcomes in DRIs.
e. Risk factor reduction and other intermediate outcomes? | Low (progression to type 2 diabetes and LV mass / function: (ACE inhibitor vs. ARB); | There was no evidence for an impact of ACE inhibitors, ARBs, or DRIs on glucose or A1c, and no included studies evaluated rates of progression to type 2 diabetes mellitus. Although we included 13 studies of LV mass/function, these were dominated by poor-quality studies with small sample sizes, and only one study included evaluation of a DRI.
e. Risk factor reduction and other intermediate outcomes? | Insufficient (DRI vs. ACE inhibitor or ARB)
2. Key Question 2. For adult patients with essential hypertension, how do ACE inhibitors, ARBs, and DRIs differ in safety, adverse events, tolerability, persistence with drug therapy, and treatment adherence? | Cough: High (ACE inhibitor vs. ARB); Insufficient (DRI vs. ACE inhibitor or ARB) | ACE inhibitors have been consistently shown to be associated with higher risk of cough than ARBs (odds ratio 4.74; 95% CI 3.56 to 6.31). For RCTs, this translates to a difference in rates of cough of 7.8%; however, for cohort studies with lower rates of cough, this translates to a difference of 1.2%. There were only two studies comparing DRIs to ACE inhibitors and these gave an estimated odds ratio of 0.333 (95% CI of 0.2241 to 0.4933).
| Withdrawals due to adverse events: High (ACE inhibitor vs. ARB); Low (DRI vs. ACE inhibitor or ARB) | The withdrawal rate for ACE inhibitors was found to have an estimated odds ratio of 1.77 (95% CI 1.42 to 2.21) compared with ARBs. For RCTs, this translated to an absolute difference in withdrawals of 2.3% (3.1% versus 5.4%). The DRI trials did not find a statistically significant difference (odds ratio 0.886; 95% CI 0.458 to 1.714) when compared with the withdrawal rate associated with ACE inhibitors.
| Withdrawals due to adverse events: High (ACE inhibitor vs. ARB); Low (DRI vs. ACE inhibitor or ARB) | There was no evidence of differences across treatments in rates of other commonly reported specific adverse events.
| Angioedema: Low (ACE inhibitor vs. ARB); Insufficient (DRI vs. ACE inhibitor or ARB) | Although several studies collected data on angioedema, the event rates were very low or zero for all studies; this limited our ability to accurately characterize the frequency of angioedema. In the four studies that did report episodes of angioedema, this adverse event was observed only in patients treated with an ACE inhibitor (five patients from three studies) or a DRI (one patient in one study).
| Persistence with drug therapy/treatment adherence: Moderate (ACE inhibitor vs. ARB); Insufficient (DRI vs. ACE inhibitor or ARB) | ACE inhibitors and ARBs have similar rates of treatment adherence based on pill counts; this result may not be applicable outside the clinical trial setting. Rates of continuation with therapy appear to be somewhat better with ARBs than with ACE inhibitors; however, due to variability in definitions, limitations inherent in longitudinal cohort studies, and relatively small sample sizes for ARBs, the precise magnitude of this effect is difficult to quantify. The three included studies evaluating DRIs did not find evidence of differences in treatment adherence compared with ACE inhibitors or ARBs. Persistence was not evaluated in any of the studies including DRIs.
3. Key Question 3. Are there subgroups of patients – based on demographic and other characteristics (i.e., age, race, ethnicity, sex, comorbidities, concurrent use of other medications)—a for whom ACE inhibitors, ARBs, or DRIs are more effective, are associated with fewer adverse events, or are better tolerated? | Insufficient (ACE inhibitor vs. ARB; DRI vs. ACE inhibitor or ARB) | Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACE inhibitors, ARBs, and DRIs for any particular patient subgroup.

Abbreviations: ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CI = confidence interval; DRI(s) = direct renin inhibitor(s); GFR = glomerular filtration rate; LV = left ventricular; MI = myocardial infarction; OR = odds ratio; RCTs = randomized controlled trials

The 2011 updated report demonstrated that direct comparisons of ACEIs and ARBs continued to be an active area of investigation, with 59 percent more direct comparison studies in the 3 years following the publication of the original report. Nevertheless, data from these new studies have not significantly changed the conclusions, nor have they changed the strength of evidence from the original report, which suggests that this additional research was not efficiently directed at important areas of remaining uncertainty. The lack of clinically useful new information, in spite of many more new publications, is likely explained by several factors. The primary outcomes of many of the new studies were biochemical, and the clinical information abstracted from their reports was sparse. The importance of directly comparing these medications' effects on clinical outcomes is particularly important considering the mixed results of other placebo-controlled and direct comparison studies of ACE inhibitors and ARBs for these outcomes.8 The incentives for comparative effectiveness research investment differ between public funders and private, for-profit corporations. Therefore, the highest value research may not be the most likely to be funded.

AHRQ supports our Evidence-based Practice Center (EPC) to work with various stakeholders to identify and prioritize the future research that is most needed by decisionmakers. Given the clinical and economic importance of ACEI, ARB, and DRI medications, the ongoing investment in their research, and the remaining areas of uncertainty, we sought to create a prioritized research agenda that would represent the interests of diverse stakeholders and allow the remaining areas of uncertainty to be addressed. This report is a summary of that process and our findings.