# Appendixes

Appendix A Exact Search Strings

Appendix B Table of Research Priorities Linked to Recent Publications and Ongoing Studies

Appendix C Criteria for Research Prioritization