# Table of Research Priorities Linked to Recent Publications and Ongoing Studies

Priority | Details
1 | Impact of comorbidities (such as ischemic heart disease, CHF with or without preserved LV function, diabetes, peripheral arterial disease, chronic kidney disease, prior coronary revascularization; single- vs. multi-vessel coronary artery disease) on ACE-I/ARB/DRI effectiveness or harms in patients with hypertension MEDLINE: Krone W, Hanefeld M, Meyer HF, et al‥ 2011. Comparative efficacy and safety of aliskiren and irbesartan in patients with hypertension and metabolic syndrome. Journal of Human Hypertension 25 (Mar) 186-95 ClinicalTrials.gov: The Study of Novel Dual Renin Angiotensin Aldosterone System (RAAS) Blockade; Valsartan/Aliskiren in African American Patients With Hypertension and the Metabolic Syndrome, NCT01432106; RCT of 100 pts Shiga Microalbuminuria Reduction Trial-2 in Patients with Diabetes (Drug: Aliskiren and any angiotensin receptor blockers), NCT0146199; RCT of 320 pts Antiproteinuric Effect of Imidapril Versus Ramipril in Type 2 Diabetic and Hypertensive Patients With Microalbuminuria, NCT012300034, RCT of 206 pts Aliskiren Versus Ramipril on Antiproteinuric Effect in Hypertensive, Type 2 Diabetic Patients With Microalbuminuria, NCT01038895, RCT of 120 pts Aliskiren and Valsartan vs Valsartan Alone in Patients With Stage II Systolic Hypertension and Type II Diabetes Mellitus, NCT00927394, RCT of 422 pts
2 | Impact of demographic differences (such as age, race, sex) on ACE-I/ARB/DRIs effectiveness or harms in patients with hypertension MEDLINE: Duprez DA, Munger MA, Botha J, et al‥ 2010. Aliskiren for geriatric lowering of systolic hypertension: a randomized controlled trial. Journal of Human Hypertension 24 (Sep) 600-8 Mallion J-M, Omboni S, Barton J, et al‥ 2011. Antihypertensive efficacy and safety of olmesartan and ramipril in elderly patients with mild to moderate systolic and diastolic essential hypertension. Blood Pressure 20 Suppl 1 (Apr) 3-11 Malacco E, Omboni S, Volpe M, et al‥ 2010. Antihypertensive efficacy and safety of olmesartan medoxomil and ramipril in elderly patients with mild to moderate essential hypertension: the ESPORT study. Journal of Hypertension 28 (Nov) 2342-50 Verdecchia P, Calvo C, Mockel V, et al‥ 2007. Safety and efficacy of the oral direct renin inhibitor aliskiren in elderly patients with hypertension. Blood Pressure 16 (#date#) 381-91 ClinicalTrials.gov: The Study of Novel Dual Renin Angiotensin Aldosterone System (RAAS) Blockade; Valsartan/Aliskiren in African American Patients With Hypertension and the Metabolic Syndrome, NCT01432106; RCT of 100 pts
3 | Impact of genetic differences (such as ACE or angiotensin II receptor gene polymorphisms) on ACE-I/ARB/DRI effectiveness or harms MEDLINE: Moore N, Dicker P, O'Brien JK, et al‥ 2007. Renin gene polymorphisms and haplotypes, blood pressure, and responses to renin-angiotensin system inhibition. Hypertension 50 (Aug) 340-7 ClinicalTrials.gov: Ocsaar and CYP2C9 Ploymorphism, Is There a Connection Between Pharmacokinetics, Pharmacodynamics and Pharmacogenetics?, NCT00732966, RCT of 30 pts
4 | Impact of health risk behaviors such as diet, exercise, smoking, alcohol intake on ACE-I/ARB/DRI effectiveness or harms MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found
5 | Impact of the dose response (impact of medication dose or dosing interval) of ACE-I/ARB/DRI on their effectiveness or harms MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found
6 | Differential impact of specific agents or subclasses (based on tissue specificity, chemical properties, or pharmacokinetics) within each medication class on ACE-I/ARB/DRI effectiveness or harms MEDLINE: Ohishi M, Takeya Y, Tatara Y, et al‥ 2010. Strong suppression of the renin-angiotensin system has a renal-protective effect in hypertensive patients: high-dose ARB with ACE inhibitor (Hawaii) study. Hypertension Research - Clinical & Experimental 33 (Nov) 1150-4 ClinicalTrials.gov: The Clinical Study to Evaluate the Efficacy and Safety of Fimasartan in Patients With Mild to Moderate Essential Hypertension (Fimasartan vs. Candesartan), NCT01135212, RCT of 288 pts Antiproteinuric Effect of Imidapril Versus Ramipril in Type 2 Diabetic and Hypertensive Patients With Microalbuminuria, NCT012300034, RCT of 206 pts Ocsaar and CYP2C9 Ploymorphism, Is There a Connection Between Pharmacokinetics, Pharmacodynamics and Pharmacogenetics?, NCT00732966, RCT of 30 pts Valsartan and Amlodipine Compared to Losartan and Amlodipine in Hypertensive Patients, NCT00716950, RCT of 187 pts
7 | The benefit of ACE-I/ARB/DRI relative to alternative medication classes (calcium channel blocker, diuretic, or beta-blocker) with respect to their effectiveness or harms MEDLINE: Jordan J, Engeli S, Boye SW, et al‥ 2007. Direct Renin inhibition with aliskiren in obese patients with arterial hypertension. Hypertension 49 (May) 1047-55 ClinicalTrials.gov: No relevant citations found Systematic reviews: Bangalore S, Kumar S, Wetterslev J, et al‥ 2011. Angiotensin receptor blockers and risk of myocardial infarction: meta-analyses and trial sequential analyses of 147 020 patients from randomised trials. BMJ 342 (#date#) d2234 Petrella R and Michailidis P. 2011. Retrospective analysis of real-world efficacy of angiotensin receptor blockers versus other classes of antihypertensive agents in blood pressure management. Clin Ther 33 (Sep) 1190-203 Sciarretta S, Palano F, Tocci G, et al‥ 2011. Antihypertensive treatment and development of heart failure in hypertension: a Bayesian network meta-analysis of studies in patients with hypertension and high cardiovascular risk. Arch Intern Med 171 (Mar 14) 384-94 Van Bortel LM, Fici F and Mascagni F. 2008. Efficacy and tolerability of nebivolol compared with other antihypertensive drugs: a meta-analysis. Am J Cardiovasc Drugs 8 (#date#) 35-44 Vijan S. 2009. Diabetes: treating hypertension. Clin Evid (Online) 2009 (#date#) #pages# Wald DS, Law M, Morris JK, et al‥ 2009. Combination therapy versus monotherapy in reducing blood pressure: meta-analysis on 11,000 participants from 42 trials. Am J Med 122 (Mar) 290-300 Webb AJ, Fischer U, Mehta Z, et al‥ 2010. Effects of antihypertensive-drug class on interindividual variation in blood pressure and risk of stroke: a systematic review and meta-analysis. Lancet 375 (Mar 13) 906-15 Wright JM and Musini VM. 2009. First-line drugs for hypertension. Cochrane Database Syst Rev #volume# (#date#) CD001841
8 | Impact of concurrent medications(such as antiplatelet agents, lipid-lowering medications, diuretics, other antihypertensives) on ACE-I/ARB/DRI effectiveness or harms MEDLINE: O'Brien E, Barton J, Nussberger J, et al‥ 2007. Aliskiren reduces blood pressure and suppresses plasma renin activity in combination with a thiazide diuretic, an angiotensin-converting enzyme inhibitor, or an angiotensin receptor blocker. Hypertension 49 (Feb) 276-84 Vaidyanathan S, Valencia J, Kemp C, et al‥ 2006. Lack of pharmacokinetic interactions of aliskiren, a novel direct renin inhibitor for the treatment of hypertension, with the antihypertensives amlodipine, valsartan, hydrochlorothiazide (HCTZ) and ramipril in healthy volunteers. International Journal of Clinical Practice 60 (Nov) 1343-56 ClinicalTrials.gov: Comparison of Sevikar® and the Combination of Perindopril/Amlodipine on Central Blood Pressure (ACE + CCB vs. ARB + CCB), NCT 01101009, RCT of 720 pts Systematic reviews: Wald DS, Law M, Morris JK, et al‥ 2009. Combination therapy versus monotherapy in reducing blood pressure: meta-analysis on 11,000 participants from 42 trials. Am J Med 122 (Mar) 290-300
9 | The impact of ACE I, ARB, or DRI monotherapy compared to ACE I, ARB, and/or DRI combination therapy in essential hypertension MEDLINE: Persson F, Lewis JB, Lewis EJ, et al‥ 2011. Aliskiren in combination with losartan reduces albuminuria independent of baseline blood pressure in patients with type 2 diabetes and nephropathy. Clinical Journal of The American Society of Nephrology: CJASN 6 (May) 1025-31 Geiger H, Barranco E, Gorostidi M, et al‥ 2009. Combination therapy with various combinations of aliskiren, valsartan, and hydrochlorothiazide in hypertensive patients not adequately responsive to hydrochlorothiazide alone. Journal of Clinical Hypertension 11 (Jun) 324-32 Solomon SD, Appelbaum E, Manning WJ, et al‥ 2009. Effect of the direct Renin inhibitor aliskiren, the Angiotensin receptor blocker losartan, or both on left ventricular mass in patients with hypertension and left ventricular hypertrophy. Circulation 119 (Feb 3) 530-7 Yarows SA, Oparil S, Patel S, et al‥ 2008. Aliskiren and valsartan in stage 2 hypertension: subgroup analysis of a randomized, double-blind study. Advances in Therapy 25 (Dec) 1288-302 Parving H-H, Persson F, Lewis JB, et al‥ 2008. Aliskiren combined with losartan in type 2 diabetes and nephropathy.[Reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID: 19291865]. New England Journal of Medicine 358 (Jun 5) 2433-46 Uresin Y, Taylor AA, Kilo C, et al‥ 2007. Efficacy and safety of the direct renin inhibitor aliskiren and ramipril alone or in combination in patients with diabetes and hypertension. Journal of the Renin-Angiotensin-Aldosterone System 8 (Dec) 190-8 Oparil S, Yarows SA, Patel S, et al‥ 2007. Efficacy and safety of combined use of aliskiren and valsartan in patients with hypertension: a randomised, double-blind trial.[Erratum appears in Lancet. 2007 Nov 3;370(9598):1542]. Lancet 370 (Jul 21) 221-9 Pool JL, Schmieder RE, Azizi M, et al‥ 2007. Aliskiren, an orally effective renin inhibitor, provides antihypertensive efficacy alone and in combination with valsartan. American Journal of Hypertension 20 (Jan) 11-20 ClinicalTrials.gov: The Study of Novel Dual Renin Angiotensin Aldosterone System (RAAS) Blockade; Valsartan/Aliskiren in African American Patients With Hypertension and the Metabolic Syndrome, NCT01432106; RCT of 100 pts Aliskiren and Valsartan vs Valsartan Alone in Patients With Stage II Systolic Hypertension and Type II Diabetes Mellitus, NCT00927394, RCT of 422 pts Systematic reviews: Arici M and Erdem Y. 2009. Dual blockade of the renin-angiotensin system for cardiorenal protection: an update. Am J Kidney Dis 53 (Feb) 332-45 Baker WL, Coleman CI, Kluger J, et al‥ 2009. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors or angiotensin II-receptor blockers for ischemic heart disease. Ann Intern Med 151 (Dec 15) 861-71 Dusing R and Sellers F. 2009. ACE inhibitors, angiotensin receptor blockers and direct renin inhibitors in combination: a review of their role after the ONTARGET trial. Curr Med Res Opin 25 (Sep) 2287-301 Probstfield J. 2009. Defining the role of renin/angiotensin-targeted antihypertensive therapy in decreasing cardiovascular risk: evidence, guideline evolution, and questions to be resolved. J Fam Pract 58 (Jun) S1-8 Zhenfeng Z, Huilan S, Junya J, et al‥ 2011. A systematic review and meta-analysis of aliskiren and angiotension receptor blockers in the management of essential hypertension. J Renin Angiotensin Aldosterone Syst 12 (Jun) 102-12
10 | The impact of ACE-I/ARB/DRI alone compared to ACE-I/ARB/DRI combined with aldosterone receptor antagonists MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: Bomback AS, Kshirsagar AV, Amamoo MA, et al‥ 2008. Change in proteinuria after adding aldosterone blockers to ACE inhibitors or angiotensin receptor blockers in CKD: a systematic review. Am J Kidney Dis 51 (Feb) 199-211 Navaneethan SD, Nigwekar SU, Sehgal AR, et al‥ 2009. Aldosterone antagonists for preventing the progression of chronic kidney disease: a systematic review and meta-analysis. Clin J Am Soc Nephrol 4 (Mar) 542-51
11 | The impact of ACE-I/ARB/DRI alone compared to ACE-I/ARB/DRI in combination with a diuretic MEDLINE: O'Brien E, Barton J, Nussberger J, et al‥ 2007. Aliskiren reduces blood pressure and suppresses plasma renin activity in combination with a thiazide diuretic, an angiotensin-converting enzyme inhibitor, or an angiotensin receptor blocker. Hypertension 49 (Feb) 276-84 Pool JL, Schmieder RE, Azizi M, et al‥ 2007. Aliskiren, an orally effective renin inhibitor, provides antihypertensive efficacy alone and in combination with valsartan. American Journal of Hypertension 20 (Jan) 11-20 ClinicalTrials.gov: No relevant citations found Systematic reviews: Morimoto S, Takahashi N, Morita T, et al‥ 2010. Critical appraisal and pooled analysis of telmisartan alone or in combination with hydrochlorothiazide for achieving blood pressure goals. Integr Blood Press Control 3 (#date#) 73-9 Wald DS, Law M, Morris JK, et al‥ 2009. Combination therapy versus monotherapy in reducing blood pressure: meta-analysis on 11,000 participants from 42 trials. Am J Med 122 (Mar) 290-300
12 | Studies of cardiovascular and cerebrovascular events compared across the three medication classes thereby requiring evaluation of outcomes over several years MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found
13 | Evaluation of cancer-related outcomes, which are infrequently reported in the existing literature MEDLINE: Collaboration ARBT. 2011. Effects of telmisartan, irbesartan, valsartan, candesartan, and losartan on cancers in 15 trials enrolling 138,769 individuals. Journal of Hypertension 29 (Apr) 623-35 ClinicalTrials.gov: No relevant citations found Systematic reviews: Bangalore S, Kumar S, Kjeldsen SE, et al‥ 2011. Antihypertensive drugs and risk of cancer: network meta-analyses and trial sequential analyses of 324,168 participants from randomised trials. Lancet Oncol 12 (Jan) 65-82 Chang CH, Lin JW, Wu LC, et al‥ 2011. Angiotensin receptor blockade and risk of cancer in type 2 diabetes mellitus: a nationwide case-control study. J Clin Oncol 29 (Aug 1) 3001-7 Coleman CI, Baker WL, Kluger J, et al‥ 2008. Antihypertensive medication and their impact on cancer incidence: a mixed treatment comparison meta-analysis of randomized controlled trials. J Hypertens 26 (Apr) 622-9 Mc Menamin UC, Murray LJ, Cantwell MM, et al‥ 2011. Angiotensin-converting enzyme inhibitors and angiotensin receptor blockers in cancer progression and survival: a systematic review. Cancer Causes Control #volume# (Nov 25) #pages# Sipahi I, Chou J, Mishra P, et al‥ 2011. Meta-analysis of randomized controlled trials on effect of angiotensin-converting enzyme inhibitors on cancer risk. Am J Cardiol 108 (Jul 15) 294-301 Sipahi I, Debanne SM, Rowland DY, et al‥ 2010. Angiotensin-receptor blockade and risk of cancer: meta-analysis of randomised controlled trials. Lancet Oncol 11 (Jul) 627-36 Yoon C, Yang HS, Jeon I, et al‥ 2011. Use of angiotensin-converting-enzyme inhibitors or angiotensin-receptor blockers and cancer risk: a meta-analysis of observational studies. CMAJ 183 (Oct 4) E1073-84
14 | Evaluation of the incidence, timing, and clinical consequences of angioedema in patients treated with ACEIs, ARBs, or DRIs MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found
15 | The impact of ACE-I/ARB/DRI on incidence of new cardiovascular or metabolic diagnoses (such as diabetes, atrial fibrillation, CHF with or without preserved LV function) MEDLINE: Fogari R, Zoppi A, Salvadeo SAT, et al‥ 2011. Fibrinolysis and insulin sensitivity in imidapril and candesartan (FISIC study) recipients with hypertension. Hypertension Research - Clinical & Experimental 34 (Apr) 509-15 Al-Mallah M, Khawaja O, Sinno M, et al‥ 2010. Do angiotensin converting enzyme inhibitors or angiotensin receptor blockers prevent diabetes mellitus? A meta-analysis. Cardiology Journal 17 (#date#) 448-56 Shariff N, Zelenkofske S, Eid S, et al‥ 2010. Demographic determinants and effect of pre-operative angiotensin converting enzyme inhibitors and angiotensin receptor blockers on the occurrence of atrial fibrillation after CABG surgery. BMC Cardiovascular Disorders 10 (#date#) 7 Schaer BA, Schneider C, Jick SS, et al‥ 2010. Risk for incident atrial fibrillation in patients who receive antihypertensive drugs: a nested case-control study.[Summary for patients in Ann Intern Med. 2010 Jan 19;152(2):I-16; PMID: 20083810]. Annals of Internal Medicine 152 (Jan 19) 78-84 ClinicalTrials.gov: Imidapril and Candesartan on Fibrinolysis and Insulin-Sensitivity in Patients With Mild to Moderate Hypertension, NCT00644475, RCT of 60 pts
16 | The impact of ACE-I/ARB/DRI on patient health status including quality of life and functional capacity MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found
17 | The impact of ACE-I/ARB/DRI on utilization and cost of therapy MEDLINE: Chang J, Yang W, Kahler KH, et al‥ 2011. Compliance, persistence, healthcare resource use, and treatment costs associated with aliskiren plus ARB versus ACE inhibitor plus ARB combination therapy: in US patients with hypertension. American Journal of Cardiovascular Drugs 11 (#date#) 21-32 ClinicalTrials.gov: No relevant citations found Systematic reviews: Lang CD, Arora RR, Saha SA, et al‥ 2008. Bayesian meta-analysis of tissue angiotensin-converting enzyme inhibitors for reduction of adverse cardiovascular events in patients with diabetes mellitus and preserved left ventricular function. J Cardiometab Syndr 3 (Winter) 45-52 Tavakoli M, Pumford N, Woodward M, et al‥ 2009. An economic evaluation of a perindopril-based blood pressure lowering regimen for patients who have suffered a cerebrovascular event. Eur J Health Econ 10 (Feb) 111-9 Theodoratou D, Maniadakis N, Fragoulakis V, et al‥ 2009. Analysis of published economic evaluations of angiotensin receptor blockers. Hellenic J Cardiol 50 (Mar-Apr) 105-18
18 | The impact of ACE-I/ARB/DRI on progression of renal insufficiency or development of dialysis dependence MEDLINE: Persson F, Lewis JB, Lewis EJ, et al‥ 2011. Aliskiren in combination with losartan reduces albuminuria independent of baseline blood pressure in patients with type 2 diabetes and nephropathy. Clinical Journal of The American Society of Nephrology: CJASN 6 (May) 1025-31 Wong J, Molyneaux L, Constantino M, et al‥ 2010. Beyond ONTARGET: angiotensin-converting enzyme inhibition and angiotensin II receptor blockade in combination, a lesser evil in some?. Diabetes, Obesity & Metabolism 12 (Dec) 1072-8 Ohishi M, Takeya Y, Tatara Y, et al‥ 2010. Strong suppression of the renin-angiotensin system has a renal-protective effect in hypertensive patients: high-dose ARB with ACE inhibitor (Hawaii) study. Hypertension Research - Clinical & Experimental 33 (Nov) 1150-4 Persson F, Rossing P, Reinhard H, et al‥ 2009. Renal effects of aliskiren compared with and in combination with irbesartan in patients with type 2 diabetes, hypertension, and albuminuria. Diabetes Care 32 (Oct) 1873-9 Parving H-H, Persson F, Lewis JB, et al‥ 2008. Aliskiren combined with losartan in type 2 diabetes and nephropathy.[Reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID: 19291865]. New England Journal of Medicine 358 (Jun 5) 2433-46 ClinicalTrials.gov: The Study of Novel Dual Renin Angiotensin Aldosterone System (RAAS) Blockade; Valsartan/Aliskiren in African American Patients With Hypertension and the Metabolic Syndrome, NCT01432106; RCT of 100pts Shiga Microalbuminuria Reduction Trial-2 in Patients with Diabetes (Drug: Aliskiren and any angiotensin receptor blockers), NCT0146199; RCT of 320 pts Antiproteinuric Effect of Imidapril Versus Ramipril in Type 2 Diabetic and Hypertensive Patients With Microalbuminuria, NCT012300034, RCT of 206 pts Aliskiren Versus Ramipril on Antiproteinuric Effect in Hypertensive, Type 2 Diabetic Patients With Microalbuminuria, NCT01038895, RCT of 120 pts ALiskiren or Losartan Effects on bioMARKers of Myocardial Remodeling, NCT01176032, RCT of 296 pts
19 | The impact of ACE-I/ARB/DRI on development of non-angioedema adverse effects (such as hypotensive symptoms, cough, syncope, diarrhea, renal insufficiency, hyperkalemia) MEDLINE: Duprez DA, Munger MA, Botha J, et al‥ 2010. Aliskiren for geriatric lowering of systolic hypertension: a randomized controlled trial. Journal of Human Hypertension 24 (Sep) 600-8 Mallion J-M, Omboni S, Barton J, et al‥ 2011. Antihypertensive efficacy and safety of olmesartan and ramipril in elderly patients with mild to moderate systolic and diastolic essential hypertension. Blood Pressure 20 Suppl 1 (Apr) 3-11 Malacco E, Omboni S, Volpe M, et al‥ 2010. Antihypertensive efficacy and safety of olmesartan medoxomil and ramipril in elderly patients with mild to moderate essential hypertension: the ESPORT study. Journal of Hypertension 28 (Nov) 2342-50 Spinar J, Vitovec J, Soucek M, et al‥ 2010. CORD: COmparison of Recommended Doses of ace inhibitors and angiotensin II receptor blockers. International Journal of Cardiology 144 (Oct 8) 293-4 Stanton AV, Gradman AH, Schmieder RE, et al‥ 2010. Aliskiren monotherapy does not cause paradoxical blood pressure rises: meta-analysis of data from 8 clinical trials. Hypertension 55 (Jan) 54-60 Geiger H, Barranco E, Gorostidi M, et al‥ 2009. Combination therapy with various combinations of aliskiren, valsartan, and hydrochlorothiazide in hypertensive patients not adequately responsive to hydrochlorothiazide alone. Journal of Clinical Hypertension 11 (Jun) 324-32 Parving H-H, Persson F, Lewis JB, et al‥ 2008. Aliskiren combined with losartan in type 2 diabetes and nephropathy.[Reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID: 19291865]. New England Journal of Medicine 358 (Jun 5) 2433-46 Andersen K, Weinberger MH, Egan B, et al‥ 2008. Comparative efficacy and safety of aliskiren, an oral direct renin inhibitor, and ramipril in hypertension: a 6-month, randomized, double-blind trial. Journal of Hypertension 26 (Mar) 589-99 Uresin Y, Taylor AA, Kilo C, et al‥ 2007. Efficacy and safety of the direct renin inhibitor aliskiren and ramipril alone or in combination in patients with diabetes and hypertension. Journal of the Renin-Angiotensin-Aldosterone System 8 (Dec) 190-8 Verdecchia P, Calvo C, Mockel V, et al‥ 2007. Safety and efficacy of the oral direct renin inhibitor aliskiren in elderly patients with hypertension. Blood Pressure 16 (#date#) 381-91 Strasser RH, Puig JG, Farsang C, et al‥ 2007. A comparison of the tolerability of the direct renin inhibitor aliskiren and lisinopril in patients with severe hypertension. Journal of Human Hypertension 21 (Oct) 780-7 Oparil S, Yarows SA, Patel S, et al‥ 2007. Efficacy and safety of combined use of aliskiren and valsartan in patients with hypertension: a randomised, double-blind trial.[Erratum appears in Lancet. 2007 Nov 3;370(9598):1542]. Lancet 370 (Jul 21) 221-9 Pool JL, Schmieder RE, Azizi M, et al‥ 2007. Aliskiren, an orally effective renin inhibitor, provides antihypertensive efficacy alone and in combination with valsartan. American Journal of Hypertension 20 (Jan) 11-20 Mallion J-M, Omboni S, Barton J, et al‥ 2011. Antihypertensive efficacy and safety of olmesartan and ramipril in elderly patients with mild to moderate systolic and diastolic essential hypertension. Blood Pressure 20 Suppl 1 (Apr) 3-11 ClinicalTrials.gov: Aliskiren and Valsartan vs Valsartan Alone in Patients With Stage II Systolic Hypertension and Type II Diabetes Mellitus, NCT00927394, RCT of 422 pts ALiskiren or Losartan Effects on bioMARKers of Myocardial Remodeling, NCT01176032, RCT of 296 pts
20 | Relative medication adherence and persistence with drug therapy across the different classes of drugs MEDLINE: Chang J, Yang W, Kahler KH, et al‥ 2011. Compliance, persistence, healthcare resource use, and treatment costs associated with aliskiren plus ARB versus ACE inhibitor plus ARB combination therapy: in US patients with hypertension. American Journal of Cardiovascular Drugs 11 (#date#) 21-32 Malacco E, Omboni S, Volpe M, et al‥ 2010. Antihypertensive efficacy and safety of olmesartan medoxomil and ramipril in elderly patients with mild to moderate essential hypertension: the ESPORT study. Journal of Hypertension 28 (Nov) 2342-50 Strasser RH, Puig JG, Farsang C, et al‥ 2007. A comparison of the tolerability of the direct renin inhibitor aliskiren and lisinopril in patients with severe hypertension. Journal of Human Hypertension 21 (Oct) 780-7 Mallion J-M, Omboni S, Barton J, et al‥ 2011. Antihypertensive efficacy and safety of olmesartan and ramipril in elderly patients with mild to moderate systolic and diastolic essential hypertension. Blood Pressure 20 Suppl 1 (Apr) 3-11 ClinicalTrials.gov: No relevant citations found
21 | Studies of the impact of health system financing, delivery, and/or organization interventions on evidence based medication prescribing and patient adherence. MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: Austin PC, Tu JV, Ko DT, et al‥ 2008. Factors associated with the use of evidence-based therapies after discharge among elderly patients with myocardial infarction. CMAJ 179 (Oct 21) 901-8 Austin PC, Tu JV, Ko DT, et al‥ 2008. Use of evidence-based therapies after discharge among elderly patients with acute myocardial infarction. CMAJ 179 (Oct 21) 895-900 Kagoma YK, Weir MA, Iansavichus AV, et al‥ 2011. Impact of estimated GFR reporting on patients, clinicians, and health-care systems: a systematic review. Am J Kidney Dis 57 (Apr) 592-601 Khan SS, Gheorghiade M, Dunn JD, et al‥ 2008. Managed care interventions for improving outcomes in acute heart failure syndromes. Am J Manag Care 14 (Dec) S273-86; quiz S287-91 Schneider PJ, Murphy JE and Pedersen CA. 2008. Impact of medication packaging on adherence and treatment outcomes in older ambulatory patients. J Am Pharm Assoc (2003) 48 (Jan-Feb) 58-63
22 | Practical clinical trials or other or other external-validity-oriented studies that compare these medications in practice settings that better represent real-world practice MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: Petrella R and Michailidis P. 2011. Retrospective analysis of real-world efficacy of angiotensin receptor blockers versus other classes of antihypertensive agents in blood pressure management. Clin Ther 33 (Sep) 1190-203
23 | Methods for synthesis of data across clinical conditions (e.g. congestive heart failure, ischemic heart disease, and chronic kidney disease) to better understand the comparative effectiveness of ACE-I, ARBs and DRIs MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: Petrella R and Michailidis P. 2011. Retrospective analysis of real-world efficacy of angiotensin receptor blockers versus other classes of antihypertensive agents in blood pressure management. Clin Ther 33 (Sep) 1190-203 Verdecchia P, Angeli F, Repaci S, et al‥ 2009. Comparative assessment of angiotensin receptor blockers in different clinical settings. Vasc Health Risk Manag 5 (#date#) 939-48
24 | Methods for individual patient data meta-analysis, to better examine subgroups in the absence of other confounders MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: No relevant citations found
25 | Impact of changing trends in outcome event rates over time on the comparative effectiveness of ACE-I, ARBs, and DRIs. MEDLINE: No relevant citations found ClinicalTrials.gov: No relevant citations found Systematic reviews: No relevant citations found