# Exact Search Strings

The exact search strings used for this project are given below.

## MEDLINE^®^ via Ovid (update of search done for original CER)

Search date: November 14, 2011

Set | Terms | Results
1 | (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. | 12976
2 | losartan/ | 5301
3 | exp angiotensin II type 1 receptor blockers/ or exp Receptors, Angiotensin/ai [Antagonists & Inhibitors] | 11741
4 | (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. | 130
5 | or/1-4 | 16740
6 | (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril or saralasin or teprotide).mp. | 25618
7 | angiotensin-converting enzyme inhibitors/ or captopril/ or cliazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ or saralasin/ or teprotide/ | 37922
8 | 6 or 7 | 41516
9 | 5 and 8 | 6538
10 | limit 9 to yr=“2010 - current” | 544
11 | limit 10 to english language | 496
12 | exp hypertension/dt | 53251
13 | 11 and 12 | 128
14 | randomized controlled trial.pt. | 321519
15 | controlled clinical trial.pt. | 83947
16 | Randomized Controlled Trials/ | 77891
17 | Random Allocation/ | 73587
18 | Double-Blind Method/ | 113895
19 | Single-Blind Method/ | 15743
20 | or/14-19 | 540647
21 | Animal/ not Human/ | 3621311
22 | 20 not 21 | 500390
23 | clinical trial.pt. | 469975
24 | exp Clinical Trial/ | 667855
25 | (clinic$ adj25 trial$).tw. | 201771
26 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | 111399
27 | Placebos/ | 30695
28 | placebo$.tw. | 134423
29 | random$.tw. | 544924
30 | Research Design/ | 65156
31 | (Latin adj square).tw. | 2982
32 | or/23-31 | 1152741
33 | 32 not 21 | 1062417
34 | Comparative Study/ | 1567956
35 | exp Evaluation Studies/ | 160340
36 | Follow-up Studies/ | 437364
37 | Prospective Studies/ | 310272
38 | (control$ or prospectiv$ or volunteer$).tw. | 2455249
39 | Cross-Over Studies/ | 29081
40 | or/34-39 | 4117015
41 | 40 not 21 | 3181350
42 | 22 or 33 or 41 | 3671587
43 | 13 and 42 | 70
44 | limit 43 to abstracts | 67
45 | (aliskiren or tekturna).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] | 523
46 | (renin inhibitor or renin inhibitors).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier] | 1099
47 | renin/ai | 1507
48 | or/45-47 | 1913
49 | 5 and 48 | 311
50 | 49 and 42 and 12 | 78
51 | 8 and 48 | 545
52 | 51 and 42 and 12 | 94
53 | 50 or 52 | 123
54 | limit 53 to english language | 110
55 | 43 or 54 | 167

## PubMed^®^ via Ovid (search for systematic reviews)

Search date: December 16, 2011

Set # | Terms | Results
#1 | ((“losartan”[MeSH Terms] OR “losartan”[tw]) OR (“valsartan”[Supplementary Concept] OR “valsartan”[tw]) OR (“telmisartan”[Supplementary Concept] OR “telmisartan”[tw]) OR (“eprosartan”[Supplementary Concept] OR “eprosartan”[tw]) OR (“candesartan”[Supplementary Concept] OR “candesartan”[tw]) OR (“irbesartan”[Supplementary Concept] OR “irbesartan”[tw]) OR (“olmesartan”[Supplementary Concept] OR “olmesartan”[tw]) OR (“angiotensin ii type 1 receptor blockers”[MeSH Terms] OR “angiotensin ii type 1 receptor blockers”[tw] OR “angiotensin ii type 1 receptor blockers”[Pharmacological Action]) OR (“losartan”[MeSH Terms] OR “losartan”[tw] OR “cozaar”[tw]) OR (“telmisartan”[Supplementary Concept] OR “telmisartan”[tw] OR “micardis”[tw]) OR (“candesartan cilexetil”[Supplementary Concept] OR “candesartan cilexetil”[tw] OR “atacand”[tw]) OR (“eprosartan”[Supplementary Concept] OR “eprosartan”[tw] OR “teveten”[tw]) OR (“irbesartan”[Supplementary Concept] OR “irbesartan”[tw] OR “avapro”[tw]) OR (“olmesartan medoxomil”[Supplementary Concept] OR “olmesartan medoxomil”[tw] OR “benicar”[tw]) OR (“valsartan”[Supplementary Concept] OR “valsartan”[tw] OR “diovan”[tw]) | 16858
#2 | (“quinapril”[Supplementary Concept] OR “quinapril”[tw]) OR (“perindopril”[MeSH Terms] OR “perindopril”[tw]) OR (“ramipril”[MeSH Terms] OR “ramipril”[tw]) OR (“captopril”[MeSH Terms] OR “captopril”[tw]) OR (“enalapril”[MeSH Terms] OR “enalapril”[tw]) OR (“benazepril”[Supplementary Concept] OR “benazepril”[tw]) OR (“trandolapril”[Supplementary Concept] OR “trandolapril”[tw]) OR (“fosinopril”[MeSH Terms] OR “fosinopril”[tw]) OR (“moexipril”[Supplementary Concept] OR “moexipril”[tw]) OR (“enalaprilat”[MeSH Terms] OR “enalaprilat”[tw]) OR (“cilazapril”[MeSH Terms] OR “cilazapril”[tw]) OR (“saralasin”[MeSH Terms] OR “saralasin”[tw]) OR (“teprotide”[MeSH Terms] OR “teprotide”[tw]) OR (“angiotensin-converting enzyme inhibitors”[MeSH Terms] OR (“angiotensin-converting”[tw] AND “enzyme”[tw] AND “inhibitors”[tw]) OR “angiotensin-converting enzyme inhibitors”[tw] OR (“angiotensin”[tw] AND “converting”[tw] AND “enzyme”[tw] AND “inhibitors”[tw]) OR “angiotensin converting enzyme inhibitors”[tw] OR “angiotensin-converting enzyme inhibitors”[Pharmacological Action]) OR (“captopril”[MeSH Terms] OR “captopril”[tw]) OR (“cilazapril”[MeSH Terms] OR “cilazapril”[tw]) OR (“enalapril”[MeSH Terms] OR “enalapril”[tw]) OR (“enalaprilat”[MeSH Terms] OR “enalaprilat”[tw]) OR (“fosinopril”[MeSH Terms] OR “fosinopril”[tw]) OR (“lisinopril”[MeSH Terms] OR “lisinopril”[tw]) OR (“perindopril”[MeSH Terms] OR “perindopril”[tw]) OR (“ramipril”[MeSH Terms] OR “ramipril”[tw]) OR (“saralasin”[MeSH Terms] OR “saralasin”[tw]) OR (“teprotide”[MeSH Terms] OR “teprotide”[tw]) | 47412
#3 | OR (“aliskiren”[Supplementary Concept] OR “aliskiren”[tw]) OR (“aliskiren”[Supplementary Concept] OR “aliskiren”[tw] OR “tekturna”[tw]) OR ((“renin”[MeSH Terms] OR “renin”[tw]) AND inhibitor[tw]) OR ((“renin”[MeSH Terms] OR “renin”[All Fields]) AND (“antagonists and inhibitors”[Subheading] OR (“antagonists”[tw] AND “inhibitors”[tw]) OR “antagonists and inhibitors”[tw] OR “inhibitors”[tw]))) OR (“Angiotensin-Converting Enzyme Inhibitors”[Mesh] OR “Angiotensin-Converting Enzyme Inhibitors”[Pharmacological Action]) OR (“Angiotensin Receptor Antagonists”[Mesh] OR “Angiotensin Receptor Antagonists”[Pharmacological Action] OR “Angiotensin II Type 2 Receptor Blockers”[Mesh] OR “Angiotensin II Type 1 Receptor Blockers”[Mesh]) OR “Renin/antagonists and inhibitors”[Mesh] OR “direct renin inhibitors”[tw] OR “DRI”[tw] OR “DRIs”[tw] | 53191
#4 | AND (English[lang] AND systematic[sb] NOT (“infant”[MeSH Terms] OR (“infant”[MeSH Terms] OR “child”[MeSH Terms] OR “adolescent”[MeSH Terms] OR (“animals”[MeSH Terms:noexp])) AND (“2008”[PDAT] : “2011”[PDAT])) AND English[lang] AND systematic[sb] AND (“2008”[PDAT] : “2011”[PDAT])) | 51550
#5 | (#1 OR #2 OR #3) AND#4 | 356