# Acknowledgments

The authors thank Megan von Isenburg, M.L.S., for help with the literature search and retrieval, and Erin LoFrese, M.S., for editorial assistance.