# Abbreviations

ACEI: angiotensin-converting enzyme inhibitor
AHRQ: Agency for Healthcare Research and Quality
ARB: angiotensin receptor blocker
CER: comparative effectiveness review
DRI: direct renin inhibitors
HHS: Department of Health and Human Services
EPC: Evidence-based Practice Center
ONTARGET: Ongoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial
PICO: population, interventions, comparators, and outcomes
RAS: renin-angiotensin system
RCT: randomized controlled trial
CHIP: Children's Health Insurance Program