# Results

## Evidence Gaps After Stakeholder Input

During the first conference call, the stakeholders reviewed and commented on the list of preliminary evidence gaps (Appendix B) gleaned from the CER. Subsequently, the project team revised the list of evidence gaps based on comments from the stakeholders (Table 2). We asked the stakeholders to prioritize 14 of the 16 evidence gaps; the project team and the stakeholders identified the remaining two gaps as methodological shortcomings relating to bias or funding issues could not be translated into research questions. These were not prioritized along with the other gaps, but the project team considered them when developing potential study design considerations. Three methods-oriented gaps, however, were prioritized along with the other gaps in the first round of prioritization because the project team (with stakeholder input) determined that these particular gaps, although they represented limitations in research methods, did not require additional evidence; the issues related to implementation rather than requiring additional empirical evidence.

Table 2 Evidence gaps after stakeholder input

Evidence Gap^a^ | KQ
NOTE: The following group of evidence gaps relate to issues thought to be applicable across all studied disorders and include issues relating to safety, long term efficacy, and subpopulations of interest. | N/A
For children, adolescents, and young adults, the extant literature is limited with regard to examining the long-term efficacy and effectiveness of 1st and 2nd generation antipsychotics in all disorders and behaviors of interest. Examples of longer term outcomes of interest may include outcomes important to parents and patients such as school performance, emotional development, or legal system interactions. | KQ 1, 2
For children, adolescents, and young adults, the extant literature is limited with regard to studies examining the long-term safety of 1st and 2nd generation antipsychotics in all disorders and behaviors of interest. Examples of long term adverse outcomes of interest may include obesity, diabetes, cardiovascular events, or tardive dyskinesia | KQ 2, 3
The extant literature is limited with regard to evidence that allows for comparisons between and within classes of 1st and 2nd generation antipsychotics for any shorter term adverse event outcome. These outcomes include sedation, EPS, weight gain/body composition, insulin resistance, sexual adverse events, and dyslipidemia | KQ 3
The extant literature is limited with regard to evidence to determine if there are differences in efficacy, effectiveness, or adverse events for population sub-groups. Sub-groups include sex, age, race/ethnicity, co-morbidities, co-treatment, history of psychosis, history of treatment failure, or duration of illness. | KQ 4
NOTE: The following 6 evidence gaps relate to specific disorders and focus not only on efficacy data from placebo controlled trials, but also on the state of the evidence as it relates to comparisons within and between the classes of 1^st^ generation and 2^nd^ generation antipsychotics. Further, these gaps discuss the state of the evidence for short and longer term outcomes. | N/A
The evidence regarding the efficacy and effectiveness of 1st or 2nd generation antipsychotics is low or insufficient for the treatment of pervasive developmental disorders, including autistic disorder, Asperger’s syndrome, and pervasive developmental disorder not otherwise specified. | KQ 1
For children, adolescents, and young adults with both attention deficit hyperactivity disorder and disruptive behavior disorders, who have failed or had inadequate response to other therapies, there is moderate strength of evidence to support 2nd generation antipsychotics when compared with placebo for improving some behavior symptoms, most notably disruptive behaviors. However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes of interest. These other outcomes include: core ADHD symptoms, anxiety, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide related behavior. | KQ 1
For older adolescents and young adults with bipolar disorder, there was moderate strength of evidence to support 2^nd^ generation antipsychotics over placebo for clinical global impressions. However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other outcomes such as: aggression, depression, manic symptoms, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide-related behavior. | KQ 1
For adolescents and young adults with schizophrenia, there was moderate strength of evidence to support 2^nd^ generation antipsychotics over placebo for several outcomes, including Children’s Global Assessment Scale (CGAS), clinical global impressions, and positive components of the Positive and Negative Symptoms Scale (PANSS). However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes such as: aggression, depression, social/occupational functioning, HRQL, legal interactions, medication adherence, patient and parent reported outcomes, and suicide related behavior. | KQ 1
There was moderate strength of evidence favoring 2^nd^ generation antipsychotics over placebo for tic symptom improvement from studies of all patients with Tourette syndrome. However, evidence is lacking with regard to other clinically meaningful outcomes for this group, and specifically for those who have failed previous treatments. Other clinically meaningful outcomes include: clinical global impressions, obsessive-compulsive symptoms, social/occupational functioning, HRQL, medication adherence, patient and parent reported outcomes, and suicide related behavior. | KQ 1
For those with Obsessive Compulsive Disorder, Eating Disorders, and Post Traumatic Stress Disorder who have failed or had inadequate treatment with other therapies, there is a paucity of data regarding the efficacy and effectiveness of 1st or 2nd generation antipsychotics. | KQ 1
NOTE: The group of gaps below relates to issues more methodological in nature and are not specific to drug class or disorder. | N/A
The extant literature is limited with regard to the consistent use of standardized pediatric side-effect scales (e.g., the Safety Monitoring Uniform Report Form). | KQ 2
The extant literature is limited with regard to consistent and comparable outcomes and outcome measurements across the studied disorders and behaviors of concern. | KQ 3, Methods
The extant literature demonstrates a lack of consensus on minimal clinically important differences within many disorders. | KQ 3, Methods
The extant literature lacks large-scale effectiveness studies that are generalizable to the broader population seen in clinical practices. | Methods, All KQs
NOTE: The following gaps were not part of the list of evidence gaps that the stakeholders prioritized. The project team considered these methodological shortcomings of existing research and the issues were of implementation rather than requiring additional empiric evidence. | N/A
The extant literature is limited with regard to efficacy studies with adequate blinding of study participants and outcome assessors, the adequate concealing of allocation and the appropriate handling and reporting of missing data. | Methods, All KQs
The extant literature is limited with regard to independent/investigator driven research efforts which increases the potential for overestimated treatment effects associated with industry-funded research. | Methods, All KQs

a All of the evidence gaps refer to the population of children, adolescents, and young adults 24 years of age or younger.

Abbreviations: ADHD=attention deficit hyperactivity disorder; CGAS=Children’s Global Assessment Scale; EPS=extra-pyramidal symptoms; HRQL=health related quality of life; KQ=key question; PANSS=Positive and Negative Symptoms Scale.

## Prioritization Results

We conducted two rounds of prioritization to ultimately identify six high-priority research needs. In the first round, the stakeholders determined that 9 of the 14 evidence gaps were of higher priority than the rest of the evidence gaps. Ten of the 12 stakeholders (83 percent) completed the first online prioritization exercise. The number of stars allocated to each evidence gap ranged from 1 to 18. Based on the distribution of the stars allotted to each gap, the upper-tier evidence gaps were the 9 gaps that received four or more stars. On reviewing the upper- and lower-tier gaps, and considering stakeholder comments, the project team removed one of the gaps from the next round of prioritization because the group considered it to be a methods gap too broad to frame as a research question. Ultimately, 8 evidence gaps moved forward to the next round of prioritization.

Between the first and second rounds of prioritization, the project team applied a PICOTS framework to the upper-tier evidence gaps and developed related research questions for each of them. Stakeholders provided input for the PICOTS framework during the second conference call. Table 3 shows the PICOTS used by the project team to develop research questions from the upper-tier evidence gaps.

Table 3 PICOTS for the upper-tier evidence gaps and related research questions prioritized in round 2

The following descriptions of PICOTS define the scope of the evidence gaps and research questions identified through the Future Research Needs for the Comparative Effectiveness of First and Second Generation Antipsychotics stakeholder engagement process. Specific outcomes may apply to one or more research questions. For example, some questions focus on health and behavioral outcomes and others focus on adverse events; the outcomes described below apply to each as appropriate.
Population
All Questions: Children, youth, and young adults (24 years of age or younger) with one or more of the following disorders: PDD, ADHD, DBD, bipolar disorder, schizophrenia/schizophrenia-related psychosis, OCD, post-traumatic stress disorder, eating disorders (anorexia nervosa, bulimia nervosa, eating disorder not otherwise specified), tic disorders (Tourette syndrome), or nondisorder-specific severe behavioral issues (e.g., aggression). For Subgroups: Demographic and clinical subgroups of children, youth, and young adults 24 years of age or younger with one or more of the disorders listed above including: age, racial groups, gender, genetically defined subgroups, socioeconomic groups, level of education, or physical and mental health comorbidities (other psychiatric disorders, treatment history, substance abuse, learning disabilities, developmental disorders, language impairments, cognitive abilities).
Interventions
All Questions: Any FDA-approved FGA or SGA
Comparators
All Questions: Any other FDA-approved FGA or SGA, placebo, or another dose of the same antipsychotic
Outcomes (Efficacy or Effectiveness)
Disorder/illness-specific symptom-related outcomes: The following symptom domains are examples of domains of interest for each disorder or illness and not an exhaustive list of all potential outcomes that might be measured:; - PDDs: repetitive behaviors, social/communication, agitation/aggression; - ADHD and DBDs: impulsivity, defiant behavior, aggressive behavior; - Bipolar disorder: mania, depression; - Schizophrenia and related psychoses: positive and negative symptoms, cognitive function; - Obsessive compulsive disorder: obsession severity, compulsion severity; - Post-traumatic stress disorder: re-experiencing, avoidance behaviors; - Anorexia nervosa/bulimia nervosa/eating disorder NOS; metabolic/nutritional, purging frequency/intensity; - Tourette syndrome; tic severity; Nondisorder-specific behaviors of interest: The following are examples of key common nondisorder-specific behaviors of interest that could be considered when evaluating efficacy/effectiveness: aggression, agitation, anxiety, behavioral dyscontrol, irritability, mood lability, self-injurious behaviors, and sleep disorders.
Outcomes (Related to Key Psychiatric Comorbidities)
The following are examples of key co-morbidities for the specific disorders of interest listed above that could also be considered when evaluating efficacy/effectiveness.; - PDDs: ADHD, anxiety disorders; - ADHD and DBDs: Substance abuse, depression, anxiety disorders; - Bipolar disorder: ADHD, substance abuse/dependence; - Schizophrenia and related psychoses: Depression, substance abuse/dependence,; - OCD: Tourette syndrome/tic severity, ADHD; - PTSD: Depression, substance abuse; - Anorexia nervosa/bulimia nervosa/eating disorder NOS: Depression; - Tourette syndrome: ADHD, OCD
Outcomes (Harms or Adverse Events)
Medication-associated adverse events, withdrawal due to adverse events, persistence and reversibility of adverse events. Examples of major adverse events include the following:; - Mortality; - Cerebrovascular disease-related events; - Development of diabetes mellitus; - Diabetic ketoacidosis; - Neuroleptic malignant syndrome; - Seizures; - Tardive dyskinesia; - Cardiomyopathies; - Cardiac arrhythmias; - Agranulocytosis; - Extrapyramidal effects; General adverse event examples include the following:; - Weight gain (e.g., using body mass index growth charts); - Agitation; - Constipation; - Sedation; - Elevated cholesterol; - Elevated transaminases; - Adverse events related to prolactin elevations; - Galactorrhea/bloody galactorrhea; - Exercise intolerance; - Precocious puberty
Outcomes (Other Short-Term and Long-Term Outcomes)
- Response rates with corresponding dose, duration of response, remission, relapse, speed of response, time to discontinuation of medication; - Growth and maturation; - Cognitive and emotional development; - Suicide-related behaviors or death by suicide; - Medication adherence and persistence; - School performance/attendance; - Work-related functional capacity; - Patient insight into illness; - High-risk behavior outcomes (i.e., unintended pregnancy, accidental injury/death, sexually transmitted disease, substance abuse); - Patient or parent/care provider reported outcomes, including levels of physical activity/inactivity, diet (i.e., caloric intake, food preferences); - Health-related quality of life; - Relationship functioning; - Legal/justice system interaction (i.e., arrests, detention); - Health care system utilization (e.g., hospitalization rates, medication costs, outpatient expenditures); - “Outcomes that matter” to children, youth and young adults, and their families. These functional outcomes may reflect a developmental perspective.
Timing
- Short term: ≤ 6 months; - Long term: > 6 months, generally years
Settings
All settings, including inpatient hospitalization and outpatient treatment, and practice-based research networks

Abbreviations: ADHD=attention deficit hyperactivity disorder; DBD=disruptive behavior disorder; FDA=U.S. Food and Drug Administration; FGA=first-generation antipsychotics; NOS=not otherwise specified; OCD=obsessive-compulsive disorder; PDD=pervasive developmental disorder; PICOTS=populations, interventions, comparators, outcomes, time frames, and settings; PTSD=post traumatic stress syndrome; SGA=second-generation antipsychotics

Table 4 shows the list of 8 evidence gaps and related research questions that the stakeholders prioritized in the second round. Ten out of 12 stakeholders (83 percent) completed the second round of prioritization. The results are shown in Figure 2. The number of stars allotted to each research need ranged from 3 to 17. Out of eight high -priority evidence gaps, six were deemed by the stakeholders as the highest-priority research needs.

Table 4 Upper-tier evidence gaps and related research needs prioritized in round 2

Evidence Gap (EG) 1 For children, adolescents, and young adults, the extant literature is limited with regard to examining the long-term efficacy and effectiveness of 1st and 2nd generation antipsychotics in all disorders and behaviors of interest. Examples of longer term outcomes of interest may include outcomes important to parents and patients such as school performance, emotional development, or legal system interactions. Key Question (KQ) 1, KQ2 Research Need (RN) 1 What is the long-term comparative effectiveness between and within classes of antipsychotics as measured in outcomes related to the disorder of interest, its co-morbidities, associated behavioral features, social-occupational outcomes, and outcomes identified as important by patients and their families?
EG2 For children, adolescents, and young adults, the extant literature is limited with regard to studies examining the long- term safety of 1st and 2nd generation antipsychotics in all disorders and behaviors of interest. Examples of long term adverse outcomes of interest may include obesity, diabetes, cardiovascular events, or tardive dyskinesia. KQ2, KQ3 RN2 What are the comparative long-term risks of medication exposure between and within antipsychotic classes?
EG3 The extant literature is limited with regard to evidence that allows for comparisons between and within classes of 1st and 2nd generation antipsychotics for any shorter term adverse event outcome. These outcomes include sedation, EPS, weight gain/body composition, insulin resistance, sexual adverse events, and dyslipidemia. KQ3 RN3 What are the comparative short-term risks of medication exposure between and within antipsychotic classes?
EG4 The extant literature is limited with regard to evidence to determine if there are differences in efficacy, effectiveness, or adverse events for population sub-groups. Sub-groups include sex, age, race/ethnicity, co-morbidities, co- treatment, history of psychosis, history of treatment failure, or duration of illness. KQ4 RN4 Are there subgroups of patients based on baseline demographic/clinical characteristics or physical and/or mental health co-morbidities for which first and second generation antipsychotics differ in efficacy, effectiveness, or frequency of adverse events?
EG6^a^ For children, adolescents, and young adults with both attention deficit hyperactivity disorder and disruptive behavior disorders, who have failed or had inadequate response to other therapies, there is moderate strength of evidence to support 2nd generation antipsychotics when compared with placebo for improving some behavior symptoms, most notably disruptive behaviors. However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes of interest. These other outcomes include: core ADHD symptoms, anxiety, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide related behavior. KQ1 RN5 What is the efficacy and effectiveness of first or second generation antipsychotics for individuals with attention deficit hyperactivity disorder and disruptive behavior disorders in the following outcome domains: core ADHD symptoms, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?
EG7 For older adolescents and young adults with bipolar disorder, there was moderate strength of evidence to support 2nd generation antipsychotics over placebo for clinical global impressions. However, the evidence regarding the efficacy and effectiveness of 1st or 2nd generation antipsychotics is low or insufficient for other outcomes such as: aggression, depression, manic symptoms, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent-reported outcomes, and suicide-related behavior. KQ1 RN6 What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with bipolar disorder in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?
EG8 For adolescents and young adults with schizophrenia, there was moderate strength of evidence to support 2^nd^ generation antipsychotics over placebo for several outcomes, including Children’s Global Assessment Scale (CGAS), clinical global impressions, and positive components of the Positive and Negative Symptoms Scale (PANSS). However, the evidence regarding the efficacy and effectiveness of 1^st^ or 2^nd^ generation antipsychotics is low or insufficient for other clinically meaningful outcomes such as: aggression, depression, social/occupational functioning, HRQL, legal interactions, medication adherence, patient and parent reported outcomes, and suicide related behavior. KQ1 RN7 What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with schizophrenia in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent reported outcomes, those related to high risk behaviors, and suicide related behavior?
EG11^a^ The extant literature is limited with regard to the consistent use of standardized pediatric side-effect scales (e.g., the Safety Monitoring Uniform Report Form). KQ2 RN8 Which new or existing tools or methods should be consistently applied in community care and/or pragmatic research settings to measure the relevant adverse effects (including behavioral side effects) related to antipsychotic usage?

a The numbers for the Evidence Gaps (EGs) correspond to the numbers assigned in the list that was prioritized, only those that emerged as the upper tier EGs are listed in this table, therefore some numbers appear out of sequence.

Figure 2 Distribution of stars among eight research needs

The vertical axis represents the number of stars assigned. The bars represent the research needs (RNs). The dashed line represents the cutoff point between the upper-tier and lower-tier research needs. All research needs with five or more stars represent the stakeholders’ highest priority research needs.

Figure 2. Distribution of stars among eight research needs: This figure is a bar graph showing the distribution of stars among the eight research questions considered by the stakeholders in the second round of prioritization. Each research question was assigned a variable code RN1 through RN8. These variable codes appear along the horizontal axis of the graph. The vertical axis on the left shows numbers 0 through 18. The number of stars for each research need is as follows: RN1 = 15; RN2 = 17; RN3 = 4; RN4 = 11; RN5 = 9; RN6 = 7; RN7 = 3; RN8 = 14. A dashed line runs from left to right at the level of number 5 to represent the cut-off point between the upper tier and lower tier. The needs that received 5 stars or more represent the upper tier of the stakeholders’ prioritized research needs. These are RN1, RN2, RN4, RN5, RN6, and RN8. RN3 and RN7 are in the lower tier.

## Highest Priority Research Needs: PICOTS Information and Considerations of Potential Research Designs

For each of the six highest-priority research needs below, we state the need in the form of a research question, highlight key points of the stated need, and describe considerations for research designs. The PICOTS that define the populations, interventions, comparators, outcomes, time frames, and settings for the research needs identified by the stakeholders are listed above in Table 3. This set of top-tier research needs should be considered as a whole, without any particular ranking. Design considerations are focused on maximum reduction of bias and feasibility to maximize probability of completion. A general description of potential study designs for these research needs is included in Appendix G.

### Research Need What is the long-term comparative effectiveness between and within classes of antipsychotics as measured in outcomes related to the disorder of interest, its co-morbidities, associated behavioral features, social-occupational outcomes, and outcomes identified as important by patients and their families?

#### Considerations for Potential Research Designs

A well-designed RCT is an ideal design but not likely to have sufficient power to detect differences between and within classes of antipsychotics for all long-term outcomes of interest. Although random assignment is the best way to avoid biased estimates of treatment effects, a number of factors may make randomized trials difficult in this research area. Child research participants (or their parents) may often be unwilling to accept random assignment to treatment. Further, where there is a perceived or real lack of equipoise (e.g., in comparing FGAs versus SGAs), random assignment may be neither ethical nor acceptable to participants. Finally, randomized trials are resource intensive, and many of the research questions (e.g., between-drug effectiveness comparisons) may require large samples because of small treatment effects.

Therefore, the following designs could be considered:

- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design

[underlined: Nonrandomized Comparative Design]: For this population, a nonrandomized type of design would allow researchers to attend to challenges of examining long-term outcomes in this population. Treatment may be assigned on the basis of provider or practice. Remaining challenges for this specific research need include handling high levels of psychiatric comorbidity for some disorders of interest, lack of consensus on disease phenomenology and nosology within the field for some disorders of interest, and high levels of concern regarding selection bias (for example, children who receive antipsychotics may have more behavioral severity and are, therefore, less able to participate in clinical research). Some of the outcomes of interest for the research needs discussed here may exist in some studies, but the heterogeneity of the study populations and the outcomes (and measurement tools used) has not allowed for meta-analysis on most topics of interest.

[underlined: Observational Studies], such as prospective and retrospective cohort designs, are also useful for addressing the complex comparative effectiveness questions raised in this research need. Although similar to nonrandomized comparative designs (trials in which treatment is not assigned at random), cohort design participants (or their parents) are allowed to select interventions. Registries of antipsychotic-exposed individuals with linkages to clinical datasets such as outpatient and pharmacy claims data and/or electronic medical record (EMR) systems will be important but are only beginning to develop in the US and Canada. Practice based research networks in child mental health may also be vehicles for evaluating the needs below but such platforms are nascent in this field.

### Research Need What are the comparative long-term risks of medication exposure between and within antipsychotic classes?

#### Considerations for Potential Research Designs

Similar to the previous research need, a well-designed RCT is an ideal design but not likely to have sufficient power to detect differences between and within classes of antipsychotics in terms of change in harms for all long-term outcomes of interest. Therefore, the following designs could be considered:

- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design

### Research Need What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with schizophrenia in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent reported outcomes, those related to high risk behaviors, and suicide related behavior? Outcomes include aggression, depression, social/occupational functioning, health related quality of life (HRQL), legal interactions, medication adherence, patient and parent reported outcomes, and suicide related behavior.

#### Considerations for Potential Research Designs

Similar to the previous research needs, a well-designed RCT is an ideal design but not likely to have sufficient power to detect differences along the outcomes of interest given the focus on adolescents and young adults with schizophrenia. Thus, for this research need, the study designs listed below could be considered:

- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design
  ○ Case control study

### Research Need Are there subgroups of patients based on baseline demographic/clinical characteristics or physical and/or mental health co-morbidities for which first and second generation antipsychotics differ in efficacy, effectiveness, or frequency of adverse events? Sub-groups include sex, age, race/ethnicity, co-morbidities, co-treatment, history of psychosis, history of treatment failure, or duration of illness.

#### Considerations for Potential Research Designs

For this research need, the study designs listed below could be considered:

- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design
  ○ Meta-analysis of individual patient data. This type of evaluation is appropriate for gathering information on the comparative long-term risks of antipsychotic medication exposure between and within antipsychotic classes. Another appropriate design would involve pooling data from existing trials for simultaneous data analysis. Advantages of this study design for producing a valid result include increased statistical power, increased ability to account for sample heterogeneity, and increased frequency of low-base rate behaviors/harms. Similar to NRCTs, careful consideration of selection bias and unmeasured confounders need to be controlled for results to be definitive and to get closer to drawing causal inferences. Integration of multiple-armed trials would allow testing of several hypotheses regarding agents. However, use of this study design requires the existence of underlying databases with common data definitions and willingness of investigators to pool data. Appendix G lists additional relevant characteristics and considerations of this design.

### Research Need What is the efficacy and effectiveness of first or second generation antipsychotics for individuals with attention deficit hyperactivity disorder and disruptive behavior disorders in the following outcome domains: core ADHD symptoms, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?

#### Considerations for Potential Research Designs

For this research need, the study designs listed below could be considered:

- Randomized comparative designs
- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design
  ○ Case control study
  ○ Meta-analysis of individual patient data

### Research Need What is the efficacy and effectiveness of first or second generation antipsychotics for adolescents and young adults with bipolar disorder in the following outcome domains: core features of the disorder, its commonly associated co-morbidities and behavioral features, social/occupational functioning, patient and parent-reported outcomes, those related to high risk behaviors, and suicide related behavior?

#### Considerations for Potential Research Designs

For this research need, the study designs listed below could be considered:

- Randomized comparative designs
- Nonrandomized comparative designs
- Observational studies
  ○ Prospective cohort design
  ○ Retrospective cohort design
  ○ Case control study
  ○ Meta-analysis of individual patient data

Similar to other disorder-specific needs, data from multiple studies can be pooled, and propensity matching can be used to compare outcomes of interventions. Also, registry studies, possibly using paired electronic health records or claims data, may allow for evaluation of some questions. Key considerations are whether the available data from such databases have the outcomes of interest noted.

## Sample Size Requirements

This section provides a simple framework for thinking about the sample size requirements associated with common study designs that could be used to address one or more of the highest-priority research needs. The examples focus on relatively simple comparisons of benefits or harms between two drugs or between a drug and placebo. Studies to establish equivalence between two drugs would require larger sample sizes and different analysis techniques. Comparisons of more than two drugs would require somewhat larger total sample sizes (for example, see Cohen12) as well as consideration of the increase in Type I error (the probability of finding an effect where none exists) associated with multiple comparisons.

The sample size estimates assume statistical power of 0.80 and a two-tailed significance level of 0.05. These estimates are approximate, and they do not account for design improvements that could increase power, such as the use of repeated measures or the inclusion of covariates to increase the precision of estimates.

### Sample Size Estimate Example 1: Comparison of Means

This example applies to randomized and nonrandomized trials and to prospective and retrospective cohort studies. The example involves a continuous measure of an adverse effect but is also applicable to beneficial outcomes (i.e., efficacy or effectiveness studies); this example is relevant to a number of Research Needs.

Correll et al.13 studied cardiometabolic risk in 205 children and adolescents with psychotic, mood, or aggressive behavior disorders who were untreated or newly treated with quetiapine, risperidone, aripiprazole, or olanzapine. For 12-week weight gain, the authors reported within-drug effect sizes (ESs) of 0.04, 0.77, 0.77, 0.84, and 0.97, respectively.(The average weight gain for the four antipsychotics ranged from 8 percent to 15 percent of baseline weight, above the usual clinical significance threshold of ≥7 percent). Table 5 shows that in a cohort study finding a within-drug adverse effect similar in magnitude to the minimum 12-week weight gain above (ES, 0.77) would require a sample of 14 (the sample size listed for an effect size of 0.80 and one sample). Finding a drug-placebo difference equivalent to the minimum difference between drug and no treatment (ES, 0.73, assuming that the effect sizes reported for weight gain were based on a common denominator) would require about 29 people per group (the sample size listed for an effect size of 0.75 and two samples).

Table 5 Approximate sample size required per group for comparisons of means14 (two-tailed test, α=.05, power=.80)

Effect Size | One Sample (Paired) | Two Samples
0.10 | 787 | 1,571
0.15 | 351 | 699
0.20 | 198 | 393
0.25 | 128 | 252
0.30 | 89 | 175
0.35 | 66 | 129
0.40 | 51 | 99
0.45 | 41 | 78
0.50 | 33 | 64
0.55 | 28 | 53
0.60 | 24 | 45
0.65 | 21 | 38
0.70 | 18 | 33
0.75 | 16 | 29
0.80 | 14 | 26

Table 6 highlights the substantially greater number of participants necessary to test directly small effects such as differences in weight gain among SGAs. Even if a between-drug difference were equivalent to the maximum between-drug difference in the study by Correll et al.13 (ES, 0.20, or an average gain of 15 percent versus 8 percent relative to baseline weight), detecting that difference would require a much larger sample size, approximately 393 per group (ES, 0.20, two samples).

Table 6 Approximate sample size required per group for comparisons of two proportions19

Proportion (Drug A)
Proportion (Drug B or Placebo) | .20 | .30 | .35 | .40 | .45 | .50 | .55 | .60 | .65 | .70
.10 | 199 | 62 | 43 | 32 | 25 | 20 | 16 | 15^a^ | 14 a | 13 a
.20 | | 294 | 138 | 82 | 54 | 39 | 29 | 23 | 18 | 15
.30 | | | 1,377 | 356 | 163 | 93 | 61 | 42 | 31 | 24
.35 | | | | 1,471 | 376 | 170 | 96 | 62 | 43 | 31
.40 | | | | | 1,534 | 388 | 173 | 97 | 62 | 42
.45 | | | | | | 1,565 | 392 | 173 | 96 | 61
.50 | | | | | | | 1,565 | 388 | 170 | 93
.55 | | | | | | | | 1,534 | 376 | 163
.60 | | | | | | | | | 1,471 | 356
.65 | | | | | | | | | | 1,377

a To maintain expected cell counts of at least 5 for valid statistical inference, the minimum sample size per group is increased slightly.

### Sample Size Estimate Example 2: Comparison of Proportions

This example applies to randomized and nonrandomized trials, prospective and retrospective cohort studies, and case-control studies. The example involves dichotomous measures of efficacy or effectiveness but is also applicable to studies of adverse effects.

In an industry-sponsored clinical trial, Tohen et al.15 compared olanzapine with placebo in the treatment of 161 adolescents with bipolar mania. They measured response rates of 44.8 percent and 18.5 percent, respectively, and remission rates of 35.2 percent and 11.1 percent, respectively, defining response as a ≥50 percent reduction in the Young Mania Rating Scale score and remission as having an endpoint score of ≤12. Haas et al.16 compared two risperidone dose regimens with placebo in 169 youths from the same population. Based on the same definition of treatment response, they found response rates of 59 percent and 63 percent in the treatment group (depending on dose regimen) and a response rate of 26 percent in the placebo group. In this pair of trials, the minimum difference between drug and placebo (i.e., the difference in remission rates between olanzapine and placebo in the study by Tohen et al.15) was approximately 35 percent versus 10 percent (OR, 4.85; equivalent ES, 0.87^17^). All other things being equal, this effect would be considered clinically significant because the number needed to treat is only four.18 (Number needed to treat, or NNT, is the number of people who would need to be treated for one additional person to experience remission.) In a new study, if one hypothesized a difference in remission rates of 35 percent (Drug A) versus 10 percent (placebo), Table 6 shows that finding an effect of this size would require a sample of 43 people per group. Generally, compared with the efficacy trials cited here, effectiveness studies are likely to involve even smaller effects because of greater heterogeneity in the patient populations and less control over experimental conditions. Therefore, effectiveness studies with similar outcomes measures are likely to require larger sample sizes.

In contrast to the drug-placebo example in the preceding paragraph, the difference between response rates for low-dose risperidone (in the study by Haas et al.16) and olanzapine (in the study by Tohen et al.15) was smaller, 59 percent versus 44.8 percent (OR, 1.77; equivalent ES, 0.32; NNT, 7). In a new study, if one hypothesized a difference in response rates of 60 percent (Drug A) versus 45 percent (Drug B), Table 6 shows that detecting a difference of that size would require a larger sample, about 173 people per group.

If one hypothesized response rates that were slightly lower and slightly closer together, say, 50 percent for Drug A and 40 percent for Drug B (OR, 1.5; equivalent ES, 0.22; NNT, 10), Table 6 shows that the required sample size would be about 388 subjects per group, as large as many of the largest trials in this field. We would consider such a difference clinically important because only 10 people would need to be treated with Drug A instead of Drug B for one additional person to experience treatment response, an important outcome.