# References

1 Seida JC, Schouten JR, Mousavi SS, et al. First- and Second-Generation Antipsychotics for Children and Young Adults. Comparative Effectiveness Review No. 39. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-2007-10021.) AHRQ Publication No 11(12)-EHC077-EF. Rockville, MD. Agency for Healthcare Research and Quality. February. 2012.
2 Leucht S, Corves C, Arbter D, et al. Second-generation versus first-generation antipsychotic drugs for schizophrenia: a meta-analysis. Lancet. Jan. 3. 2009;373(9657):31-41. [pmid: 19058842].
3 Haddad PM, Das A, Keyhani S, et al. Antipsychotic drugs and extrapyramidal side effects in first episode psychosis: a systematic review of head-head comparisons. J Psychopharmacol. 2011. Nov. 5. [pmid: 22057019].
4 Margetic B, Aukst-Margetic B. Neuroleptic malignant syndrome and its controversies. Pharmacoepidemiol Drug Saf. May. 2010;19(5):429-35. [pmid: 20306454].
5 Zito JM, Safer DJ, dosReis S, et al. Trends in the prescribing of psychotropic medications to preschoolers. JAMA. 2000;238(8):1025-30. [pmid: 10697062].
6 Zito JM, Safer DJ, DosReis S, et al. Psychotropic practice patterns for youth: a 10 year perspective. Arch Pediatric Adolesc Med. 2003;157(1):17-25. [pmid: 12517190].
7 Zito JM, Safer DJ, de Jong-van den Berg LT, et al. A three-country comparison of psychotropic medication prevalence in youth. Child Adolesc Psychiatry Ment Health. 2008;121(1):26. [pmid: 18817536].
8 Zito JM, Safer DJ, Sai D, et al. Psychotropic medication patterns among youth in foster care. Pediatrics. 2008;121(1):e157-e63. [pmid: 18166534].
9 Pathak SAS, Danielyan A, et al. Psychotropic utilization and psychiatric presentation of hospitalized very young children. J Child Adolesc Psychopharmacol. 2004;14(3):433-42. [pmid: 15650500].
10 Kuehn BM. Studies shed light on risks and trends in pediatric antipsychotic prescribing. JAMA. May. 19. 2010;303(19):1901-3. [pmid: 20483961].
11 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Methods guide for effectiveness and comparative effectiveness reviews. 2008. [pmid: 21433399].
12 Cohen J. A power primer. Psychol Bull. Jul. 1992;112(1):155-9. [pmid: 19565683].
13 Correll CU, Manu P, Olshanskiy V, et al. Cardiometabolic risk of second-generation antipsychotic medications during first-time use in children and adolescents. JAMA. Oct. 28. 2009;302(16):1765-73. [pmid: 19861668].
14 Lenth RV. Java Applets for power and sample size [Computer software]. 2006–9. Available at: http://www.stat.uiowa.edu/~rlenth/Power. Accessed December 5, 2011.
15 Tohen M, Kryzhanovskaya L, Carlson G, et al. Olanzapine versus placebo in the treatment of adolescents with bipolar mania. Am J Psychiatry. Oct. 2007;164(10):1547-56. [pmid: 17898346].
16 Haas M, Delbello MP, Pandina G, et al. Risperidone for the treatment of acute mania in children and adolescents with bipolar disorder: a randomized, double-blind, placebo-controlled study. Bipolar Disord. Nov. 2009;11(7):687-700. [pmid: 19839994].
17 Chinn S. A simple method for converting an odds ratio to effect size for use in meta-analysis. Stat Med. Nov. 30. 2000;19(22):3127-31. [pmid: 11113947].
18 Citrome L. Compelling or irrelevant? Using number needed to treat can help decide. Acta Psychiatr Scand. Jun. 2008;117(6):412-9. [pmid: 18479317].
19 Brant R. Inference for proportions: comparing two independent samples [Computer software]. Available at: http://www.stat.ubc.ca/~rollin/stats/ssize/b2.html. Accessed December 6, 2011.